# RESULTS

## LITERATURE FLOW

The literature searches yielded 1022 citations in MEDLINE and 931 citations in CINAHL. Combining the results and removing duplicates yielded 1789 citations. We excluded 1629 studies at the abstract stage and another 117 after full-text review. Many of the excluded studies were observational studies that provided contextual information about adherence or compliance but did not meet inclusion criteria. We added 7 articles (including 6 trials published prior to 2011 identified from existing systematic reviews) resulting in a total of 50 included articles: 25 trials reported in 27 articles, 10 with information about implementation barriers and facilitators, and 13 systematic reviews.

Figure 2 Literature Flow Chart

## KEY QUESTION 1 What is the comparative effectiveness of ERAS versus usual care or a subset of ERAS components for adults undergoing elective colorectal surgery?

### Overview of Studies

#### Open Surgery Studies

Sixteen studies (15 RCTs, 1 CCT) compared open surgery with an enhanced recovery protocol to open surgery with a conventional (usual care) protocol.^22-37^ Three of these studies also reported results for laparoscopic surgery with an enhanced recovery protocol compared to laparoscopic surgery with a conventional protocol (see below).^25,34,35^ We rated 4 studies low risk of bias, 4 medium risk of bias, 3 high risk of bias, and 5 unclear risk of bias. Study details are provided in Appendix D, Table 1.

No studies were conducted in the US. There were 6 from China,^23,27,32,35-37^ 3 from the United Kingdom,^22,24,28^ and one each from Italy,^31^ India,^30^ Greece,^25^ the Netherlands,^34^ Romania,^26^ Switzerland,^29^ and the Czech Republic.^33^

Seven studies included patients undergoing elective surgery for colorectal cancer.^23,26-28,32,36,37^ Three studies reported the percentage of colon and rectal surgeries.^23,26,28^ One study enrolled patients age 70 and older.^27^ Sample sizes in the colorectal cancer studies ranged from 62^37^ to 597.^32^ Mean or median ages ranged from 55 to 73 years; in the study of elderly patients, the mean age was 75 years. The study population was more than 55% male in all but one study.^28^ Three studies reported BMI with values of 22,^37^ 22.5,^32^ and 24.^23^ No study included participants with preoperative American Society of Anesthesiologists (ASA) physical status classification IV.

Five studies included mixed groups of patients – colorectal cancer or benign conditions,^22,24,29,34,35^ though the majority of participants underwent surgery for colon cancer. Sample sizes in these studies ranged from 25^22^ to 191^34^ with mean or median ages ranging from 55 to 68 years. In all but one study,^22^ more than 50% of participants were male. All 5 studies reported BMI with mean or median values of 27 or lower. As with the colorectal cancer studies, no colorectal cancer/benign condition study included participants with preoperative ASA score IV.

Two studies included patients undergoing rectal cancer surgery.^25,31^ Both enrolled fewer than 100 patients. Mean ages were 67^31^ and 64^25^ years and more than 50% were male. Mean BMI was 28 in one study;^25^ the other reported that 38% had a BMI less than 25.^31^ In one study, 88% were ASA I or II;^25^ in the other, 90% were ASA II or III.

The remaining 2 studies enrolled patients undergoing colorectal surgery that was primarily non-cancer related. In the study from India, 3% of participants had a cancer diagnosis^30^ while in the study from the Czech Republic,^33^ 7% had a cancer diagnosis and 78% had Crohn's disease. Sample sizes in the 2 studies were 60 and 103, respectively, with mean ages of 34 and 36 years. Approximately 50% were male in both studies; neither reported BMI or ASA scores.

#### Laparoscopic Studies

Eleven studies (8 RCTs, 3CCTs) compared an enhanced recovery program to usual care in patients undergoing laparoscopic surgery for colorectal conditions.^25,34,35,38-46^ Three of these studies also reported results for open surgery (see above).^25,34,35^ Five studies were from China^35,38,44-46^ and 3 were from Italy,^40,41,43^ with one each from Japan,^42^ Greece,^25^ and The Netherlands.^34^ Three were rated unclear risk of bias, 5 medium risk of bias, 2 high risk of bias, and one low risk of bias. Study details are provided in Appendix D, Table 1.

Five studies included patients with colon cancer^35,44,45^ or colorectal cancer.^42,46^ Sample sizes ranged from 78^46^ to 320.^42^ One study enrolled patients over 65 years; median ages were 71 in the enhanced recovery group and 72 in the usual care group.^46^ In the other 4 studies, mean or median ages were in the 50s^35,44,45^ or 60s.^42^ Across the 4 studies, 47%^45^ to 66%^35^ were male and in 3 studies reporting BMI, means or medians were 22 to 24.^35,44,45^ No study reporting ASA included grade IV; 2 studies excluded ASA III or IV.^42,45^

One study included 209 patients with cancer and benign conditions^34^ and 2 included patients with cancer (69%-75%) or diverticular disease (25%-31%).^40,41^ In the study with cancer and benign conditions, mean age was 57 years, 58% were male, and mean BMI was 26.^34^ Patients with ASA IV were excluded. In the studies with cancer and diverticular disease, the mean or median ages were 66 years, approximately 50% were male, and mean BMI was 26.5.^40,41^ ASA IV was also an exclusion criterion. A subgroup analysis of one of these studies included only patients 70 years of age and older.^39^

Two studies enrolled patients exclusively with rectal cancer.^25,38^ Mean ages were 55 years in a study of 116 patients^38^ and 66 years in a study of 75 patients.^25^ In one study the populations was 66% male with a mean BMI of 22.^38^ In the second study, the population was 44% male with a mean BMI of 28.^25^ One study excluded patients with ASA III or IV^38^; in the other study there were no patients with ASA IV.^25^

One study enrolled 227 women with bowel endometriosis.^43^ Mean age was 35 years and mean BMI was 22.

We identified one additional report of laparoscopic surgery with enhanced recovery compared to usual perioperative care in elderly patients with colorectal cancer.^47^ However, the authenticity of the paper has been questioned.^48^ We do not report findings from this study.

#### Mixed Open and Laparoscopic Study

One low risk of bias RCT included 324 patients who underwent either open or laparoscopic surgery (the surgeon's choice) for colon (46%) or rectal (54%) disease.^49,50^ Overall, 79% of cases were malignant. Median ages were 65 (ERAS group) and 66 (usual care group), 54% were male, and 63% were ASA II. A subgroup analysis divided patients into 3 age groups: ≤65 years, 66 to 79 years, and ≥80 years.^49^

### Enhanced Recovery Components

Ljungqvist et al organized the ERAS components into 4 phases: preadmission, preoperative, intraoperative, and postoperative.^2^ We merged the ERAS components from this recent description with those from 2013 guidelines.^2,4^ We charted the enhanced recovery protocol components specified in the enhanced recovery protocols and usual care protocols for each of the studies included in our review (Appendix E). Some studies used identical protocols resulting in 24 unique protocols (13 for open surgery, 10 for laparoscopic surgery, and one for open or laparoscopic surgery). We tracked 3 preadmission components, 8 preoperative components, 6 intraoperative components, and 9 postoperative components.

We found wide variation in the number of enhanced recovery components contained in the study protocols. Of 26 possible enhanced recovery components, enhanced recovery group protocols were found to include between 4 and 18 enhanced recovery components (4 studies with fewer than 10 components, 10 studies with 10-12 components, 8 studies with 13-15 components, and 2 studies with more than 15 components). The standard care group protocols included between 0 and 10 enhanced recovery components (16 with 0-2 components, 4 with 3-6 components, and 4 with more than 6 components).

The number of studies including each component (in either the enhanced recovery protocol or the usual care protocol) is presented in Table 1. No study included the preadmission components. Of the preoperative components, the most frequently included in enhanced recovery protocols were carbohydrate treatment, no routine use of mechanical bowel preparation, and a fasting protocol allowing clear fluids until 2 hours before surgery and solid until 6 hours before surgery. Eight protocols from our included studies had 2 or fewer of the 8 preoperative components, 2 had 3 components, 6 had 4 components, 6 had 5 components, and 2 had 6 components.

Table 1 Count of ERAS Components in Study Protocols for ERAs and Standard Care

Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation | 0 | 0
PREADMISSION | Nutritional screening/support | 0 | 0
PREADMISSION | Medical optimization of chronic disease | 0 | 0
PREOPERATIVE | Structured information/patient and caretaker engagement | 12 | 0
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | 16 | 2
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | 16 | 3
PREOPERATIVE | Carbohydrate treatment | 18 | 0
PREOPERATIVE | Thrombosis prophylaxis | 4 | 2
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | 11 | 8
PREOPERATIVE | Nausea and vomiting prophylaxis | 5 | 2
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use) | 3 | 0
INTRAOPERATIVE | Minimal invasive surgical techniques | 2+10 Lap | 0+10 Lap
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | 16 | 9
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | 14 | 3
INTRAOPERATIVE | Restrictive use of surgical site drains | 15 | 5
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | 21 | 5
INTRAOPERATIVE | Control of body temperature | 9 | 4
POSTOPERATIVE | Early mobilization | 22 | 4
POSTOPERATIVE | Early intake of oral fluids and solids | 23 | 1
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | 18 | 2
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents | 7 | 1
POSTOPERATIVE | Protein and energy-rich nutritional supplements | 11 | 0
POSTOPERATIVE | Glucose control | 1 | 0
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | 21 | 6
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting | 0 | 0
POSTOPERATIVE | Prepare for early discharge | 2 | 1

Of the 6 intraoperative components, the most frequently included were removal of nasogastric tubes before reversal of anesthesia (and no routine use of nasogastric tubes) and a standardized anesthesia protocol. One study protocol included only one intraoperative component. Most protocols included between 3 and 5 components. One protocol from a study of laparoscopic surgery included all 6 components.

Among the 9 postoperative components, early intake of oral fluids and solids was included in all enhanced recovery protocols. Other frequently included components were early mobilization, multimodal approach to opioid-sparing pain control, and early removal of urinary catheters and intravenous fluids. One protocol included only one postoperative component. The rest included at least 2 of the 9 components, with most including between 4 and 6 components.

### Overview of Outcomes

Table 2 provides an overview of outcomes reported. An “up arrow” (↑) indicates a statistically significant benefit with the enhanced recovery protocol compared to the usual care protocol. A “side-to-side arrow” (↔) indicates results were not significantly different between the enhanced recovery protocol and the usual care protocol. A “down arrow” (↓) indicates a significantly worse outcome with the enhanced recovery protocol compared to the usual care protocol. Complete outcomes data are provided in Appendix D, Tables 2-6. Outcome reporting varied across studies. No study reported on all our outcomes. All studies reported a measure of length of stay. Most studies reported on mortality, perioperative complications (including overall morbidity), hospital readmissions, and some aspect of gastrointestinal function. Few studies reported on clinically meaningful changes in quality of life or pain.

Table 2 Summary of Outcomes (Enhanced Recovery vs Usual Care)

Author Year Population | Length of Stay | Overall Mortality | Overall Morbidity | Readmissions | Quality of Life (Clinically Meaningful Change) | Pain (Clinically Meaningful Change) | Gastrointestinal Function | | | Surgical Complications | | | | Non-Surgical Complications
Author Year Population | Length of Stay | Overall Mortality | Overall Morbidity | Readmissions | Quality of Life (Clinically Meaningful Change) | Pain (Clinically Meaningful Change) | Ileus | Time to Oral Solid Foods | Other (eg, Flatus, Bowel Movement) | Surgical Site Infection | Bleeding | Need for Re-operation | Other Surgical Complication | Foley Catheter Re-insertion/Complication | Aspiration Pneumonia/Pulmonary Infection
OPEN SURGERY STUDIES
Feng 2016^23^ Colorectal cancer | ↑^b^ | | ↑ | | | | ↔ | ↑ | ↑ | ↔ | ↔ | | ↔ | | ↔
Pappalardo 2016^31^ Rectal cancer | ↑ | ↔ | | | | | | | ↑ | | | | ↔
Jia 2014^27^ Colorectal cancer (elderly) | ↑ | ↔ | | | | | | | ↑ | ↔ | | | ↔ | | ↑
Nanavati 2014^30^ Gastrointestinal surgery (3% cancer) | ↑ | ↔ | | ↔ | | | ↔ | | ↑ | ↔ | | ↔ | ↔
Gouvas 2012^25^ CCT Rectal cancer | ↑^c^ | ↔ | ↔ | ↔ | | | ↑ | | ↑ | | ↔ | ↔ | ↔ | | ↑
Ren 2011^32^ Colorectal cancer | ↑ | ↔ | ↔ | | | | | | ↑ | ↔ | | | ↔
Wang 2012^35^ Colon cancer | ↑^a^ | ↔ | ↔ | ↔ | | | | | | | | | ↔
Yang 2012^37^ Colorectal cancer | ↑ | | ↔ | ↔ | | | | ↑ | ↑ | ↔ | | | ↔ | | ↔
Vlug 2011^34^ Cancer and benign disease | ↑^c^ | ↔ | ↔ | ↔ | | | ↔ | ↑ | ↑ | ↔ | | ↔ | ↔
Wang 2011^36^ Colorectal cancer | ↑ | ↔ | ↑ | ↔ | | | | | ↑ | ↔ | | ↔ | ↔ | ↔
Ionescu 2009^26^ Rectosigmoid (58%) or colon (42%) cancer | ↑ | | | ↔ | | | | ↑ | ↑ | ↔ | | ↔ | ↔
Muller 2009^29^ Colon surgery (87% malignant) with primary anastomosis | ↑ | | ↑ | ↔ | | | ↔ | | | ↔ | ↔ | | ↔ | | ↔
Šerclová 2009^33^ Intestinal resection (78% Crohn's disease, 7% cancer) | ↑ | ↔ | ↑ | ↔ | | ↑ | | ↑ | ↑ | | | | ↑
Khoo 2007^28^ Colon (67%) or rectal (33%) cancer | ↑^c^ | ↔ | | ↔ | | | | ↑ | ↑ | | | | ↔ | ↔
Gatt 2005^24^ Colon surgery (69% malignant) | ↑^c^ | ↔ | ↔ | ↔ | | | ↔ | ↑ | | ↔ | | | | | ↔
Anderson 2003^22^ Colon surgery (72% malignant) | ↑ | ↔ | | ↔ | | | ↔ | ↑ | | ↔
LAPAROSCPIC SURGERY STUDIES
Ota 2017^42^ CCT Colorectal cancer | ↑ | ↔ | | ↔ | | | ↔ | ↑ | ↑ | ↔ | mixed | ↔ | ↔
Scioscia 2017^43^ Bowel endometriosis | ↑ | | | ↔ | | | | | | | ↔ | ↔
Mari 2016^40^ Colorectal cancer (75%) or diverticular disease (25%) | ↑ | ↔ | ↔ | | | | ↔ | ↑ | mixed | ↔ | ↔ | | ↔ | | ↔
Wang 2015^45^ CCT Colon cancer | ↑ | ↔ | ↔ | | ↔ | ↔ | ↔ | | ↑ | ↔ | | | ↔ | | ↔
Feng 2014^38^ Rectal cancer | ↑ | ↔ | ↑ | ↔ | | | ↔ | | ↑ | ↔ | | ↔ | ↔ | | ↔
Mari 2014^41^ Colon cancer (69%) or diverticular disease (31%) | ↑ | ↔ | ↔ | ↔ | | | | ↑ | ↑ | | | | ↔
Gouvas 2012^25^ CCT Rectal cancer | ↑ | ↔ | ↑ | ↔ | | | ↔ | | ↑ | | ↔ | ↔ | ↔ | | ↔
Wang 2012^35^ Colon cancer | ↑^a^ | ↔ | ↔ | ↔ | | | | | | | | | ↔
Wang 2012^44^ Colon cancer | ↑^a^ | ↔ | ↔ | ↔ | | | | ↑ | ↑ | ↔ | | ↔ | ↔ | ↔
Wang 2012^46^ Colorectal cancer (elderly) | ↑ | | ↑ | | | | | | ↑ | ↔ | | | ↔ | | ↔
Vlug 2011^34^ Cancer and benign disease | ↑ | ↔ | ↔ | ↔ | | | ↔ | ↔ | ↑ | ↔ | | ↔ | ↔
MIXED OPEN AND LAPAROSCOPIC SURGERY STUDIES
Forsmo 2016^50^ Colorectal cancer and benign disease | ↑ | ↔ | ↔ | ↔ | | | ↔ | ↔ | ↑ | ↔ | | ↔ | ↔ | | ↔

↑=benefit with enhanced recovery protocol

↔=no difference between enhanced recovery protocol and usual care protocol

↓=poorer outcome with enhanced recovery protocol

mixed=more than one outcome and results varied

a total length of stay

b calculated P value

c median values (reported in study) indicate benefit with enhanced recovery protocol; calculated means (Figure 3) indicate no benefit

Figure 3 Pooled Analysis for Length of Stay

#### Length of Stay

All but one of the included studies reported mean or median length of stay. In most studies, this was the “initial” length of stay following the surgery date. In 2 studies, one of which provided data for both open surgery and laparoscopic surgery, readmissions were also considered providing a “total” length of stay.^35,44^ Excluding those 2 studies, mean length of stay ranged from 3.0 to 8.5 days in the enhanced recovery group and 6.0 to 13.2 days in the control group. All studies found a reduced length of stay in the enhanced recovery group compared to the usual care group. Pooling results from the studies reporting initial length of stay yielded a mean difference of -2.59 days (95% CI -3.22, -1.97) (Figure 3). Statistical heterogeneity was high (I^2^=92%). Quality of evidence for reduced length of stay with enhanced recovery protocols compared to usual care protocols was rated as moderate (Table 3 and Appendix F).

Table 3 Summary of Findings for ERAS Compared to Control for Colorectal Surgeries

Outcome N[underlined: o] of participants (studies) | Relative effect (95% CI) | Anticipated absolute effects (95% CI) | | | Quality | What happens
Outcome N[underlined: o] of participants (studies) | Relative effect (95% CI) | Without ERAS | With ERAS | Difference | Quality | What happens
Length of stay N[underlined: o] of participants: 3787 (24 RCTs) | | | | MD 2.6 days lower (3.2 lower to 2.0 lower) | ⊕⊕⊕○ MODERATE^a,b^ | Duration of hospital stay was lower with ERAS in both open and laparoscopic procedure groups compared with respective control groups. Subgroup results based on condition were comparable to the overall findings.
Mortality N[underlined: o] of participants: 3255 (22 RCTs) | OR 1.79 (0.81 to 3.95) | 0.6% | 1.0% (0.4 to 2.1) | 0.4% more (0.1 fewer to 1.6 more) | ⊕⊕○○ LOW ^a,c^ | No statistically significant differences between groups.
Perioperative morbidity N[underlined: o] of participants: 2919 (19 RCTs) | RR 0.66 (0.54 to 0.80) | 29.1% | 19.2% (15.7 to 23.3) | 9.9% fewer (13.4 fewer to 5.8 fewer) | ⊕⊕⊕○ MODERATE ^a^ | Fewer complications in both open and laparoscopic ERAS groups versus respective controls. Subgroup results based on condition were comparable to the overall findings.
Readmissions N[underlined: o] of participants: 2515 (19 RCTs) | RR 1.11 (0.82 to 1.50) | 6.4% | 7.1% (5.2 to 9.6) | 0.7% more (1.1 fewer to 3.2 more) | ⊕⊕○○ LOW ^a,d^ | No statistically significant differences between groups.
Surgical site infection N[underlined: o] of participants: 2880 (17 RCTs) | RR 0.75 (0.52 to 1.07) | 4.8% | 3.6% (2.5 to 5.1) | 1.2% fewer (2.3 fewer to 0.3 more) | ⊕⊕○○ LOW ^a,d^ | No statistically significant differences between groups.

* The risk in the intervention group (and its 95% confidence interval) is based on the assumed risk in the comparison group and the relative effect of the intervention (and its 95% CI).

CI: Confidence interval; MD: Mean difference; RR: Risk ratio; OR: Odds ratio

GRADE Working Group grades of evidence

- High quality: We are very confident that the true effect lies close to that of the estimate of the effect
- Moderate quality: We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different
- Low quality: Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect
- Very low quality: We have very little confidence in the effect estimate: The true effect is likely to be substantially different from the estimate of effect

Explanations

a Mostly moderate, high or unclear risk of bias

b I-square indicated substantial statistical heterogeneity although all but 2 studies reported lower duration with ERAS. Strong association observed.

c Wide confidence intervals and very few events

d Wide confidence intervals

The remaining study reported the day on which patients met discharge criteria (ie, normal oral feeding, complete canalization, drains and catheters removed, no fever, no need for intravenous therapy).^31^ The study included patients with rectal cancer undergoing open surgery. Overall, patients in the enhanced recovery protocol group achieved discharge status sooner than those in the traditional care group (P<.05) with 68% of the enhanced recovery group patients and 16% of the traditional care group meeting criteria on post-operative day 4. All of the enhanced recovery group patients met discharge criteria by post-operative day 6 while 28% of the traditional care group did not meet criteria until post-operative day 7 or longer.

#### All-cause Mortality

All-cause mortality, typically assessed until 30 days post-surgery, was reported in 19 studies. Three of the studies^25,34,35^ reported results for both open and laparoscopic surgery, resulting in a total of 22 comparisons of enhanced recovery and usual care protocols. Mortality was generally infrequent (approximately 1%) with 10 studies reporting no deaths.^27,30-33,38,40-42,45^ No study reported a significant difference in mortality between the enhanced recovery and usual care protocols. The pooled odds ratio was 1.79 (95% CI 0.81, 3.95) (Figure 4). Quality of evidence for no difference in all-cause mortality with enhanced recovery or usual care protocols was rated as low (Table 3 and Appendix F).

Figure 4 Pooled Analysis for Mortality

#### Overall Morbidity

Perioperative morbidity was reported in 17 studies. The 3 studies reporting outcomes for both open and laparoscopic surgery reported morbidity resulting in a total of 20 comparisons of enhanced recovery and usual care protocols. One study noted no major complications in either group.^41^ In 11 of the remaining comparisons of enhanced recovery and usual care protocols, no significant difference in morbidity was observed. In 7 comparisons, overall morbidity was significantly lower in the enhanced recovery protocol groups compared to usual care. The pooled risk ratio was 0.66 (95% CI 0.54, 0.80) (Figure 5). One additional study reported the proportion of patients with one or more complications, finding no significant difference between the enhanced recovery and usual care protocols.^44^ Quality of evidence for reduced overall morbidity with enhanced recovery protocols compared to usual care protocols was rated as moderate (Table 3 and Appendix F).

Figure 5 Pooled Analysis for Morbidity

#### Readmissions

Eighteen studies (21 comparisons) reported readmissions. In one study with both open surgery and laparoscopic surgery results, readmission rates ranged from 9.5% to 15% but were not reported by group.^25^ The authors reported that differences between groups were not significant. The pooled risk ratio for studies reporting readmission rates by study group is presented in Figure 6. Five studies reported no readmissions.^22,26,33,37,41^ The pooled estimate was 1.11 (95% CI 0.82, 1.50) (absolute difference =-0.7%, 95% CI -1.1, 3.2), indicating no significant difference in risk of readmission following colorectal surgery with an enhanced recovery protocol compared to a usual care protocol. Quality of evidence for no significant difference in readmissions between enhanced recovery and usual care protocols was rated as low (Table 3 and Appendix F).

Figure 6 Pooled Analysis for Readmissions

#### Pain and Quality of Life

Few studies reported pain or quality of life outcomes (Appendix D, Tables 3 and 4). One study comparing enhanced recovery and usual care protocols associated with open surgery for benign conditions (78% Crohn's disease) reported clinically significant lower pain for the enhanced recovery group on post-operative days 0 to 5.^33^ A difference of one point on a visual analog pain scale of 0 to 10 was considered a clinically important difference. Scores ranged from 1.6 for the enhanced recovery group and 3.2 for the usual care group on the day of surgery to 0 and 1, respectively, on post-surgery day 5 (Appendix D, Table 4).

Another study, enrolling patients with colon cancer undergoing laparoscopic surgery, reported European Organization for Research and Treatment of Cancer (EORTC OLQ-C30) scores for pain and quality of life.^45^ The scale was administered pre-operatively and post-operatively and change scores were reported. A change of at least 5 points on a 0 to 100 scale was considered clinically significant with further gradations for “little,” “moderate,” or “very much” change (either better or worse). For pain, changes from before surgery to 3 days post-surgery did not differ significantly between the enhanced recovery and usual care protocol groups. Both groups experienced changes of greater than 20 points (“very much” worse pain). At post-operative day 28, the change from baseline pain was “little” worse for the enhanced recovery group and “moderate” worse for the usual care group (P=.05).

For quality of life, the change from baseline to post-operative day 3 was “moderate” for both the enhanced recovery and usual care groups but the difference between groups was significant (P<.001). By post-operative day 28, both groups rated quality of life similar to pre-surgery levels (P=.11 between groups).

Several studies reported pain scale scores without assessing whether clinically meaningful changes were observed (Appendix D, Table 4). A study of both open and laparoscopic surgery for colon cancer and benign disease reported that SF-36 Bodily Pain Scale scores returned to baseline at 4 weeks after surgery with no significant differences between enhanced recovery and usual care protocols.^34^ Another study reported no difference between groups in pain scores.^24^

Three studies reported pain scores during the post-operative period. One study of open colon surgery (72% malignant) reported that median pain scores at rest, on movement, and on coughing were significantly higher in the usual care protocol group on post-operative day 1 but by day 7, only pain on coughing was significantly higher.^22^ Two studies of laparoscopic surgery reported significantly higher pain in the enhanced recovery protocol group in the immediate post-operative period^41^ or on post-operative days 1 and 3.^38^ The first study, enrolling patients with colon cancer or diverticular disease, found the difference was not significant at 5 hours post-surgery. The enhanced recovery group experienced lower pain (although not significantly) starting on post-operative day 1.^41^ The second study, enrolling patients with rectal cancer, found higher pain in the enhanced recovery group persisted on post-operative day 3 but was not significantly different from the usual care group at post-operative day 5.^38^

One study of open rectal surgery reported quality of life scores from the EORTC OLQ-C38.^31^ The authors administered the questionnaire prior to discharge and at the 1 month follow-up but did not identify the time point associated with the reported scores. Overall, there was no significant difference between enhanced recovery and traditional care groups with 56% and 48%, respectively, reporting excellent quality of life and only 4% in each group (1 patient) reporting poor quality of life.

#### Gastrointestinal Function

Most studies reported measures of gastrointestinal function. Twelve studies (14 comparisons) reported ileus (Appendix D, Table 3). One study found significantly lower incidence of ileus in the enhanced recovery protocol group with open surgery but a non-significant difference between protocols for laparoscopic surgery.^25^ The remaining studies found no significant difference between enhanced recovery and usual care protocols for open surgery,^22-24,29,30,34^ laparoscopic surgery,^34,38,40,42,45^ or mixed open and laparoscopic surgery.^50^

Twenty studies (22 comparisons) reported significantly shorter time to flatus and/or first bowel movement in the enhanced recovery protocol group compared to the usual care protocol group (Appendix D, Table 4). The difference was observed for open surgery,^23,25-28,30-34,36,37^ laparoscopic surgery,^25,34,38,40-42,44-46^ and mixed surgery approaches^50^ across colorectal conditions.

The time to oral intake of solid foods was also significantly shorter following surgery with an enhanced recovery protocol compared to a usual care protocol in 8 open surgery^22-24,26,28,33,34,37^ and 5 laparoscopic surgery^34,40-42,44^ studies (Appendix D, Table 4). The study with mixed open and laparoscopic surgery found median days until able to tolerate solid food did not differ significantly between the enhanced recovery protocol group (2 days, range 0-9) and standard care group (1 day, range 0-12).^50^

## KEY QUESTION 2 What are the harms of ERAS versus usual care or a subset of ERAS components for adults undergoing elective colorectal surgery?

### Surgical Site Infections

Surgical site infection rates were reported in 18 studies (19 comparisons of enhanced recovery and usual care protocols) and typically infrequent in both groups (Appendix D, Table 5). No study found a significant difference in surgical site infections between the 2 protocols. One study reported total number of infections for both open surgery and laparoscopic surgery with no difference between enhanced recovery and usual care protocols within the surgery types.^34^ The remaining studies reported infection rates. Pooled results indicate no difference in the risk of surgical site infection with enhanced recovery or usual care protocols (RR 0.75 [95% CI 0.52, 1.07]) (Figure 7). Quality of evidence for no significant difference in surgical site infections between enhanced recovery and usual care protocols was rated as low (Table 3 and Appendix F).

Figure 7 Pooled Analysis for Surgical Site Infection

### Other Harms (Appendix D, Tables 5 and 6)

Few bleeding events were observed with no significant differences between enhanced recovery and usual care protocol groups for either open or laparoscopic surgery.^23,25,29,40,42,43^ Need for re-operation was reported on 10 studies (11 comparisons) with no significant differences between protocol groups for either surgery type.^25,26,30,34,36,38,42-44,50^

Many studies reported anastomotic leakage with no differences between enhanced recovery and usual care protocols for either open or laparoscopic surgery.^23,25-32,34,36-38,40-42,44-46,50^ Unspecified surgical complications either were not significantly different between enhanced recovery and usual care protocol groups^25,35,42^ or were significantly lower in the enhanced recovery protocol group.^33^

Foley catheter re-insertion was reported in 3 studies with no significant difference between enhanced recovery protocols and usual care protocols for open surgery^28,36^ or laparoscopic surgery.^44^ Pneumonia and other chest infections were reported in 11 studies (12 comparisons). Two open surgery studies found a significantly lower incidence in the enhanced recovery protocol group^25,27^ while 4 found no difference between the enhanced recovery and usual care protocols.^23,24,29,37^ Five laparoscopic studies^25,38,40,45,46^ and one study with mixed open and laparoscopic procedures^50^ found no significant difference in pulmonary infections between enhanced recovery and usual care protocol groups.

Five open surgery studies and one laparoscopic surgery study reported post-operative nausea, vomiting, or diarrhea with no significant difference between the enhanced recovery and usual care protocol groups.^24,26,32,33,35,40^ One study of elderly patients (70 to 88 years old) undergoing open surgery for colorectal cancer found post-operative delirium was significantly less likely in the enhanced recovery protocol group.^27^ Two other studies found no difference between protocol groups for delirium or post-operative confusion.^42,50^ Other commonly reported non-surgical complications with no significant differences between protocol groups included intestinal obstruction,^25,27,32,36,44,46^ urinary tract infection,^22,24,26-29,36,38,44,50^ urinary retention,^23,25,29,34,36,38,40,50^ deep vein thrombosis or pulmonary embolism,^24-27,36,38,42,44,50^ and cardiovascular and/or cerebrovascular complications.^22,27-29,31,32,34,36,37,40,42,44,45,50^

## KEY QUESTION 3 Do comparative effectiveness and harms vary by fidelity to ERAS components?

### Adherence to Specific Enhanced Recovery Components

Four studies reported adherence or compliance data. A CCT from Japan with predominantly laparoscopic surgery for colorectal cancer reported compliance (ie, the component was “applied”) with enhanced recovery components.^42^ Across 17 components, the average compliance was 85%. Seven of the 17 components were also applied in more than 50% of the conventional care group including avoidance of fluid overload, no use of drains, antimicrobial prophylaxis, epidural anesthesia, early removal of nasogastric tubes, routine postoperative laxative, and ambulation on post-operative day 1. The study reported significantly shorter length of stay in the enhanced recovery group with no differences in mortality, readmissions, or surgical site infections. Among enhanced recovery group patients, increased adherence to the protocol was associated with shorter length of stay (P=.01) but not overall rate of complications (P=.29).

In a 4-arm study with enhanced recovery and usual care groups for both open and laparoscopic surgery (mainly for colorectal cancer), 15 enhanced recovery components were evaluated for each patient.^34^ Successful application of each component was noted. A mean of 11.2 (SD 2.2) of the 15 components were applied in the laparoscopic surgery with enhanced recovery group (n=100) and 11.1 (SD 2.2) components in the open surgery with enhanced recovery group. The authors noted that “applied” does not mean that the component was successfully achieved. Vlug et al found no significant differences in mortality, overall morbidity, or hospital readmissions with enhanced recovery for either open or laparoscopic surgery. Length of stay was significantly shorter in the enhanced recovery groups compared to the usual care groups for both open and laparoscopic surgery.^34^

A study of open or laparoscopic surgery (surgeon's decision) for colorectal cancer or benign conditions reported adherence to 22 enhanced recovery components for both the enhanced recovery and standard care group.^50^ Adherence was similar in the 2 groups for 7 components: omission of bowel preparation, no preoperative fasting, no premedication, antimicrobial prophylaxis, thoracic epidural analgesia, prevention of hypothermia, and intra-operative fluid loading level. The study reported significantly shorter length of stay in the enhanced recovery group compared to standard care with no differences in overall morbidity, mortality, readmissions, or surgical site infections.

A fourth study monitored adherence to 5 enhanced recovery components (intraoperative intravenous intake, first 24-hour intravenous intake, effective epidural analgesia, mobilization time on post-operative day 1, and oral nutrition on post-operative days 1 and 4) during open surgery, mainly for colorectal cancer.^29^ The authors noted significant differences between the enhanced recovery and usual care protocol groups in median intraoperative intravenous intake, first 24-hour median intravenous intake, and oral nutrition on post-operative days 1 and 4 as evidence of “excellent compliance.” The 2 protocol groups did not differ significantly on “effective” epidural analgesia or median mobilization time on day 1. Muller et al found no difference in surgical site infections or readmissions but did report a reduction in length of stay and overall morbidity in the enhanced recovery group versus usual care.

### Inclusion of Recommended ERAS Components in a Perioperative Protocol

We used our charting of ERAS components in the enhanced recovery and standard care protocols of each of the included RCTs and CCTs to identify studies that best differentiated an enhanced recovery protocol from a standard care protocol. We looked at a) overlap of enhanced recovery components between the 2 protocols and b) inclusion of 2 enhanced recovery components that require a multidisciplinary team to successfully execute (intra-operative standardized anesthesia protocol and post-operative multimodal approach to opioid-sparing pain control). Based on these 2 criteria, we identified 11 studies (of the 25 included in the review) that appeared to best differentiate an enhanced recovery protocol from a usual care protocol.^22,23,27,28,32,33,35,36,40,44,46^ We pooled data from these 11 studies (provided they reported outcomes of interest in a way that permitted pooling) and from the remaining studies for 2 critical outcomes - length of stay (Figure 8) and overall morbidity (Figure 9). The results were similar to the overall pooled estimates with no interaction for the subgroup analysis for either outcome. Heterogeneity was substantial for the length of stay analysis (I^2^ values ≥84%) but nearly all studies favored the enhanced recovery protocol.

Figure 8 Pooled Analysis for Length of Stay in Studies with More vs Less Definitive Differentiation of ERAS vs Control Protocols

Figure 9 Pooled Analysis for Morbidity in Studies with More vs Less Definitive Differentiation of ERAS vs Control Protocols

## KEY QUESTION 4 Do comparative effectiveness and harms vary by type of, and clinical conditions for, colorectal surgery (eg, anatomical site, laparoscopic versus open surgery, reasons for open surgery, etc)?

For critical outcomes, we grouped studies by surgery type (open or laparoscopic) and by colorectal condition (colorectal cancer, rectal cancer, a mix of colorectal cancer and benign conditions, or benign conditions alone). Findings for other outcomes, including pain, quality of life, gastrointestinal function, and harms as described under Key Questions 1 and 2 (above), did not appear to differ between studies of open surgery and studies of laparoscopic surgery. We did not find outcomes reported for other subgroups of interest: comorbidity status, mobility status, frailty index, age, patient size, or right- versus left-side surgery.

### Length of Stay

Length of stay reductions due to ERAS did not significantly differ by type of, or clinical condition for, surgery. We pooled results separately for studies using laparoscopic techniques and studies using open surgery. The resulting estimates for mean difference were similar to that of the overall mean difference for both groups (Appendix G, Figure 1). The interaction was not significant (P=.69).

We also pooled results separately for studies of surgery for different colorectal conditions (colorectal cancer, rectal cancer, a mix of colorectal cancer and benign conditions, or benign conditions alone). Pooled estimates for the mean differences were similar to that of the overall mean difference for all 4 groups (Appendix G, Figure 2). The interaction was not significant (P=.29).

### All-cause Mortality

We found no difference in mortality between enhanced recovery and usual care protocols observed in studies performing open surgery or in studies performing laparoscopic surgery (Appendix G, Figure 3). The interaction was not significant (P=.43).

Across colorectal conditions, there was no difference in mortality between enhanced recovery and usual care protocols for colorectal cancer, rectal cancer, or a mix of colorectal cancer and benign conditions (Appendix G, Figure 4). The interaction was not significant (P=.42). There were no deaths in the 2 studies of benign conditions alone.^30,33^

### Overall Morbidity

Perioperative morbidity reduction between enhanced recovery and usual care protocols did not differ in studies performing open surgery and in studies performing laparoscopic surgery (Appendix G, Figure 5). The risk ratios were similar to the overall risk ratio. The interaction was not significant (P=.79).

The effect of ERAS on overall morbidity also did not vary by clinical condition (P for interaction=0.13). Perioperative morbidity was significantly lower in the enhanced recovery groups compared to usual care (Appendix G, Figure 6).

### Readmissions

No difference in risk of readmission between enhanced recovery and usual care protocols was observed in studies regardless of surgical approach (open or laparoscopic surgery) (P for interaction =.65) (Appendix G, Figure 7). The pooled risk ratio for each subset of studies was similar to the overall risk ratio.

Across colorectal conditions, risk of readmission was not significantly different between enhanced recovery and usual care protocols for colorectal cancer, rectal cancer, a mix of colorectal cancer and benign conditions, or benign conditions alone (Appendix G, Figure 8). The interaction was not significant (P=.87).

### Surgical Site Infections

No difference in surgical site infection rates between enhanced recovery and usual care protocols was observed in studies performing open surgery or in studies performing laparoscopic surgery (Appendix G, Figure 9). The pooled estimates were similar to the overall risk ratio and the interaction was not significant (P=.54).

Across colorectal conditions, risk of surgical site infection did not differ significantly between enhanced recovery and usual care protocols for colorectal cancer, rectal cancer, or a mix of colorectal cancer and benign conditions (Appendix G, Figure 10). The interaction was not significant (P=.81).

## KEY QUESTION 5 What are the barriers to and facilitators of implementation of ERAS programs?

We identified 10 studies that provided information on barriers and facilitators to implementing an enhanced recovery program. Five of the 7 studies interviewed representatives from a multidisciplinary team,^51-55^ 2 interviewed patients,^56,57^ 2 surveyed surgeons,^58,59^ and one interviewed nurses.^60^ The studies were conducted in the US,^51,59^ Canada,^53,55^ Australia/New Zealand,^54,58^ the Netherlands,^52^ and the UK.^56,57,60^ Table 4 provides an overview of the studies.

Table 4 Studies of Barriers and Facilitators

Author, year Country | Hospital type | ERAS protocol in place at time of interview/survey? | Persons interviewed/surveyed
Alawadi 2016^51^ US | Safety net hospital (single site) | No | Colorectal care surgeons, anesthesiologists, nurses; colorectal surgery patients
Keller 2016^59^ US | Not applicable | 70% of responders did not have an enhanced recovery protocol at their institution; 42% reported using enhanced recovery concepts | Surgeons, members of Society of American Gastrointestinal and Endoscopic Surgeons (SAGES)
Pearsall 2015^55^ Canada | University-affiliated adult teaching hospitals (7 sites) | No | Surgeons, anesthesiologists, ward nurses (not limited to colorectal care)
Conn 2015^53^ Canada | Academic hospitals (15 sites) | Yes; 8 sites with experience; 7 sites with limited experience | Colorectal care surgeon champions, anesthesiologist champions, nurse champions, coordinators
Lyon 2014^54^ Australia | Quaternary referral hospital (single site) | Yes | Colorectal care surgeons, stoma therapist, dietetics, physiotherapist medical administration
Ament 2014^52^ Netherlands | Hospitals that successfully implemented ERAS^a^(10 sites) | Yes | Gastrointestinal surgeons, physician assistants, coordinators, nurses
Kahokehr 2011^58^ New Zealand and Australia | Not applicable | 45% of responders routinely or “sometimes” followed a formalized ERAS pathway | Colorectal surgeons (members of Colorectal Surgical Society of Australia and New Zealand)
Jeff 2014^60^ United Kingdom | District general hospital | Yes | Ward nurses
Bernard 2014^56^ United Kingdom | Not specified | Yes | Patients
Taylor 2011^57^ United Kingdom | Tertiary colorectal unit | Yes | Patients

a Success defined as median length of stay of 6 days or less and protocol adherence rates above 70%

Adapting the framework reported by Alawadi et al,^51^ barriers and facilitators reported in the studies are organized by staff-related factors, organizational factors, and patient factors. Commonly reported barriers to implementation include time, resources, and acceptability/feasibility of protocols to clinical staff and patients. Facilitators include organizational support, sufficient staff and electronic medical record resources, clear communication that is receptive to staff/patient feedback, and standardized yet adaptable and feasible protocols.

### Staff-related Factors

Frequently mentioned staff-related barriers to implementation included difficulty adapting to change and perceived resistance to change by co-workers and colleagues from other specialty areas (Table 5). Other barriers included lack of agreement with the enhanced recovery recommendations (including a sense that there wasn't sufficient evidence to support some components) and lack of staff or staff time.

Table 5 Staff-related Barriers and Facilitators

Barriers | Facilitators
Resistance to “cook book” approach^51^ | Team cohesion/collaboration (problem solving, addressing barriers, support)^51,53,55,60^
Difficulty adapting to change (culture, personal preferences, resistance); need to change staff attitudes and behavior^51,53-55,60^ | Good communication among team members; especially if there is need to modify the protocol for specific patient needs^51,54,55^
Perceived reluctance of others to adopt components of ERAS and to work cooperatively; lack of colleague or co-specialty support^51,55,58-60^ | Creation of opportunities to build relationships across departments; avoid sense of coercion or “top-down” approach^53^
Need for flexibility to address special needs of patients^51,54,60^ | Leadership team builds a “community of practice” with other centers (networking, shared best practices)^53^
Shortened preoperative fasting may require cases to be cancelled if a patient is moved forward on the operative schedule^55^ | Physician champions^55^
Setting shortened discharge date might discourage patient if goal is not achieved^55^ | An ERAS coordinator responsible for systematic checks and monitoring of outcomes and adherence^52-55^
Lack of agreement with recommendations, don't believe in it, not enough evidence^53,55,58,60^ | Support from institution and departmental leaders^53,55,60^
Lack of staff to implement ERAS components (eg, more frequent mobilization)^55^ Lack of time^55,58^ Lack of weekend staffing for some components (eg, stoma therapy nurse) delays discharge^54^ Lack of individual confidence in following ERAS; concern about adverse consequences of accelerated patient discharge^60^ Nurses not perceiving themselves as having ownership and ability to foster development of the program^60^ Staff education^59^ Lack of awareness about enhanced recovery^59^ | Staff education (ongoing) on the evidence behind change in practice; knowledge of program^52,54,55,60^

Staff-related facilitators to implementation included strong team collaboration and communication, support from leadership, ongoing staff education, and engagement of ERAS coordinators and physician champions.

### Organizational Factors

At the organizational level, commonly mentioned barriers include lack of institutional or departmental support, lack of resources, issues with staff scheduling, and difficulty coordinating across different departments (Table 6).

Table 6 Organizational Barriers and Facilitators

Barriers | Facilitators
Need department-level “buy-in”; lack of institutional support^55,58,59^ | ERAS pathway provides evidence-based standard of care; standardized order sets would reduce variation in practice^51,53,55^
Integration of ERAS with staff scheduling^53^ | Protocol endorsed by a national organization^59^
Rotating residents could be a challenge to establishing consistency of practice^51^ | Availability and use of data to drive effective implementation; provide updates to build and sustain interest in the ERAS program (eg, data reports with uptake, outcomes)^52,53,59^
Coordinating ERAS across different departments; need for education for entire perioperative multidisciplinary team, patients, and families^51,55^ | Audit and feedback to sustain program^52,53,55^
Inconsistencies with partners or covering physicians following the same protocol^59^ | Integration of ERAS into computer order entry systems^53^
Satisfaction with current results^58^ | Administrative reminders integrated in daily practice (eg, checklists in patient files)^54^
Limited resources: equipment, staff, space^51,55,59,60^ | Embed ERAS components in local protocols and performance targets for sustainability^52^
Lack of discharge resources (ie, rural areas may lack specialist experience and facilities required to care for patients after discharge)^54^ | Cluster ERAS patients in a specific department or room^52^ Uniformity in procedure for planning and discussing timing of discharge^52^ Reaching the point where ERAS becomes the standard of care^53^

Facilitators of implementation of an enhanced recovery program included evidence-based pathways and standardized order sets, administrative reminders and/or integration of the enhanced recovery components into computer order entry systems, and use of outcomes data to build interest in the program. Setting performance targets, audit and feedback, and periodic updates were suggested as beneficial for sustaining a program.

### Patient Factors

Three studies interviewed patients,^51,56,57^ and several others mentioned patient factors related to implementation of an enhanced recovery program (Table 7). Potential barriers included the characteristics of the patient population (potentially limiting early discharge and compliance with recommendations), patient preferences and expectations (particularly related to home recovery), and concern about availability of support and community resources following discharge. Patient and family/caregiver education and early communication of expectations were mentioned as facilitators of patient acceptance of an enhanced recovery program.

Table 7 Patient Factors

Barriers | Facilitators
Characteristics of patient population served by facility (eg, high comorbidity rate, advanced disease at presentation, social support, health literacy)^51,54^ | Patient education component may increase patient satisfaction and compliance with care; family involvement^51,55,57^
Patient preferences and expectations (reflective of culture and values) might affect acceptance of ERAS program^54,55^ | Early communication with the patient about expectations and discharge^52,54,57^
Amount of patient information provided and level of complexity may need to be tailored to individual patient preferences^56^ | Frequent contact with multidisciplinary team can improve patient confidence in the rehabilitation process^57^
Lack of quiet and privacy hinders patient recovery^51^ | Patients welcomed early mobilization and speedier recovery/release^51,56,57^
Concerns about protocol being too difficult for all patients^56^ Concerns about pain control options^57^ Recovery at home hindered by inadequate instructions and education on what to expect during home recovery and difficulty contacting specialist support^51,57^ Need for support of family and friends after discharge^56^ Patient fear that early release could be unsafe (eg, complications, pain management) particularly if no social support or community resources not available^51,56^ | Patient appreciation of earlier return to usual activities following discharge^57^