# REFERENCES

1 Ljungqvist O. ERAS--enhanced recovery after surgery: moving evidence-based perioperative care to practice. JPEN J Parenter Enteral Nutr. 2014;38(5):559-566.24567343
2 Ljungqvist O, Scott M, Fearon K. Enhanced recovery after surgery: a review. JAMA Surg. 2017;152(3):292-298.28097305
3 Sehgal R, Hill A, Deasy J, McNamara DA, Cahill RA. Fast-track for the modern colorectal department. World J Surg. 2012;36(10):2473-2480.22736342
4 Gustafsson UO, Scott MJ, Schwenk W, . Guidelines for perioperative care in elective colonic surgery: Enhanced Recovery After Surgery (ERAS()) Society recommendations. World J Surg. 2013;37(2):259-284.23052794
5 Adamina M, Kehlet H, Tomlinson GA, Senagore AJ, Delaney CP. Enhanced recovery pathways optimize health outcomes and resource utilization: a meta-analysis of randomized controlled trials in colorectal surgery. Surgery. 2011;149(6):830-840.21236454
6 Bagnall NM, Malietzis G, Kennedy RH, Athanasiou T, Faiz O, Darzi A. A systematic review of enhanced recovery care after colorectal surgery in elderly patients. Colorectal Dis. 2014;16(12):947-956.25039965
7 Grant MC, Yang D, Wu C, Makary MA, Wick EC. Impact of enhanced recovery after surgery and fast track surgery pathways on healthcare-associated infections: results from a systematic review and meta-anlaysis. Ann Surg. 2017;265(1):68-79.28009729
8 Greco M, Capretti G, Beretta L, Gemma M, Pecorelli N, Braga M. Enhanced recovery program in colorectal surgery: a meta-analysis of randomized controlled trials. World J Surg. 2014;38(6):1531-1541.24368573
9 Lau CS, Chamberlain RS. Enhanced recovery after surgery programs improve patient outcomes and recovery: a meta-analysis. World J Surg. 2017;41(4):899-913.27822725
10 Launay-Savary MV, Mathonnet M, Theissen A, . Are enhanced recovery programs in colorectal surgery feasible and useful in the elderly? A systematic review of the literature. J Visc Surg. 2017;154(1):29-35.27842907
11 Li P, Fang F, Cai JX, Tang D, Li QG, Wang DR. Fast-track rehabilitation vs conventional care in laparoscopic colorectal resection for colorectal malignancy: a meta-analysis. World J Gastroenterol. 2013;19(47):9119-9126.24379639
12 Lv L, Shao YF, Zhou YB. The enhanced recovery after surgery (ERAS) pathway for patients undergoing colorectal surgery: an update of meta-analysis of randomized controlled trials. Int J Colorectal Dis. 2012;27(12):1549-1554.23001161
13 Rawlinson A, Kang P, Evans J, Khanna A. A systematic review of enhanced recovery protocols in colorectal surgery. Ann R Coll Surg Engl. 2011;93(8):583-588.22041232
14 Spanjersberg WR, Reurings J, Keus F, van Laarhoven CJ. Fast track surgery versus conventional recovery strategies for colorectal surgery. Cochrane Database Syst Rev. 2011(2):CD007635.
15 Tan SJ, Zhou F, Yui WK, . Fast track programmes vs. traditional care in laparoscopic colorectal surgery: a meta-analysis of randomized controlled trials. Hepatogastroenterology. 2014;61(129):79-84.24895798
16 Zhao JH, Sun JX, Gao P, . Fast-track surgery versus traditional perioperative care in laparoscopic colorectal cancer surgery: a meta-analysis. BMC Cancer. 2014;14:607.25148902
17 Zhuang CL, Ye XZ, Zhang XD, Chen BC, Yu Z. Enhanced recovery after surgery programs versus traditional care for colorectal surgery: a meta-analysis of randomized controlled trials. Dis Colon Rectum. 2013;56(5):667-678.23575408
18 Higgins JP, Greene S. Cochrane Handbook for Systematic Reviews of Interventions. 2011; Version 5.1.0. http://handbook-5-1.cochrane.org/. Accessed July 5, 2017.
19 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-188.3802833
20 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ 2003;327:557-560.12958120
21 Hozo SP, Djulbegovic B, Hozo I. Estimating the mean and variance from the median, range, and the size of the sample. BMC Med Res Methodol. 2005;5(1):13.15840177
22 Anderson ADG, McNaught C, MacFie J, Tring IC, Barker P, Mitchell CJ. Randomized clinical trial of multimodal optimization and standard perioperative surgical care. Br J Surg. 2003;90:1497-1504.14648727
23 Feng J, Li K, Li L, . The effects of fast-track surgery on inflammation and immunity in patients undergoing colorectal surgery. Int J Colorectal Dis. 2016;31(10):1675-1682.27517680
24 Gatt M, Anderson ADG, Reddy BS, Hayward-Sampson P, Tring IC, MacFie J. Randomized clinical trial of multimodal optimization of surgical care in patients undergoing major colonic resection. Br J Surg. 2005;92:1354-1362.16237744
25 Gouvas N, Gogos-Pappas G, Tsimogiannis K, Tsimoyiannis E, Dervenis C, Xynos E. Implementation of fast-track protocols in open and laparoscopic sphincter-preserving rectal cancer surgery: a multicenter, comparative, prospective, non-randomized study. Dig Surg. 2012;29(4):301-309.22948138
26 Ionescu D, Iancu C, Ion D, . Implementing fast-track protocol for colorectal surgery: a prospective randomized clinical trial. World J Surg. 2009;33(11):2433-2438.19707815
27 Jia Y, Jin G, Guo S, . Fast-track surgery decreases the incidence of postoperative delirium and other complications in elderly patients with colorectal carcinoma. Langenbecks Arch Surg. 2014;399(1):77-84.24337734
28 Khoo CK, Vickery CJ, Forsyth N, Vinall NS, Eyre-Brook IA. A prospective randomized controlled trial of multimodal perioperative management protocol in patients undergoing elective colorectal resection for cancer. Ann Surg. 2007;245:867-872.17522511
29 Muller S, Zalunardo MP, Hubner M, Clavien PA, Demartines N. A fast-track program reduces complications and length of hospital stay after open colonic surgery. Gastroenterol. 2009;136:842-847.
30 Nanavati AJ, Prabhakar S. A comparative study of 'fast-track' versus traditional peri-operative care protocols in gastrointestinal surgeries. J Gastrointest Surg. 2014;18(4):757-767.24222323
31 Pappalardo G, Coiro S, De Lucia F, Giannella A, Ruffolo F, Frattaroli FM. Open sphincter-preserving surgery of extraperitoneal rectal cancer without primary stoma and Fast Track Protocol. G Chir. 2016;37(6):257-261.28350972
32 Ren L, Zhu D, Wei Y, . Enhanced Recovery After Surgery (ERAS) program attenuates stress and accelerates recovery in patients after radical resection for colorectal cancer: a prospective randomized controlled trial. World J Surg. 2012;36(2):407-414.22102090
33 Šerclová Z, Dytrych P, Marvan J, . Fast-track in open intestinal surgery: prospective randomized study. Clin Nutr. 2009;28:618-624.19535182
34 Vlug MS, Wind J, Hollmann MW, . Laparoscopy in combination with fast track multimodal management is the best perioperative strategy in patients undergoing colonic surgery: a randomized clinical trial (LAFA-study). Ann Surg. 2011;254(6):868-875.21597360
35 Wang G, Jiang Z, Zhao K, . Immunologic response after laparoscopic colon cancer operation within an enhanced recovery program. J Gastrointest Surg. 2012;16(7):1379-1388.22585532
36 Wang G, Jiang ZW, Xu J, . Fast-track rehabilitation program vs conventional care after colorectal resection: a randomized clinical trial. World J Gastroenterol. 2011;17(5):671-676.21350719
37 Yang D, He W, Zhang S, Chen H, Zhang C, He Y. Fast-track surgery improves postoperative clinical recovery and immunity after elective surgery for colorectal carcinoma: randomized controlled clinical trial. World J Surg. 2012;36(8):1874-1880.22526050
38 Feng F, Li XH, Shi H, . Fast-track surgery combined with laparoscopy could improve postoperative recovery of low-risk rectal cancer patients: a randomized controlled clinical trial. J Dig Dis. 2014;15(6):306-313.24597608
39 Mari G, Costanzi A, Crippa J, . Surgical stress reduction in elderly patients undergoing elective colorectal laparoscopic surgery within an ERAS protocol. Chirurgia (Bucur). 2016;111(6):476-480.28044948
40 Mari G, Crippa J, Costanzi A, Mazzola M, Rossi M, Maggioni D. ERAS protocol reduces IL-6 secretion in colorectal laparoscopic surgery: results from a randomized clinical trial. Surg Laparosc Endosc Percutan Tech. 2016;26(6):444-448.27783027
41 Mari GM, Costanzi A, Maggioni D, . Fast-track versus standard care in laparoscopic high anterior resection: a prospective randomized-controlled trial. Surg Laparosc Endosc Percutan Tech. 2014;24(2):118-121.24686345
42 Ota H, Ikenaga M, Hasegawa J, . Safety and efficacy of an "enhanced recovery after surgery" protocol for patients undergoing colon cancer surgery: a multi-institutional controlled study. Surg Today. 2017;47(6):668-675.27688031
43 Scioscia M, Ceccaroni M, Gentile I, . Randomized trial on fast track care in colorectal surgery for deep infiltrating endometriosis. J Minim Invasive Gynecol. 2017;24(5):815-821.28435128
44 Wang G, Jiang ZW, Zhao K, . Fast track rehabilitation programme enhances functional recovery after laparoscopic colonic resection. Hepatogastroenterology. 2012;59(119):2158-2163.22366526
45 Wang H, Zhu D, Liang L, . Short-term quality of life in patients undergoing colonic surgery using enhanced recovery after surgery program versus conventional perioperative management. Qual Life Res. 2015;24(11):2663-2670.26003317
46 Wang Q, Suo J, Jiang J, Wang C, Zhao YQ, Cao X. Effectiveness of fast-track rehabilitation vs conventional care in laparoscopic colorectal resection for elderly patients: a randomized trial. Colorectal Dis. 2012;14(8):1009-1013.21985126
47 Compagna R, Aprea G, De Rosa D, . Fast track for elderly patients: is it feasible for colorectal surgery? Int J Surg. 2014;12 Suppl 2:S20-22.25159546
48 Paduraru M. Fast-track for elderly patients - critical observations on two trials. Int J Surg. 2017;2017:215-217.
49 Forsmo HM, Erichsen C, Rasdal A, Korner H, Pfeffer F. Enhanced recovery after colorectal surgery (ERAS) in elderly patients is feasible and achieves similar results as in younger patients. Gerontol Geriatr Med. 2017;3:1-8.
50 Forsmo HM, Pfeffer F, Rasdal A, . Compliance with enhanced recovery after surgery criteria and preoperative and postoperative counselling reduces length of hospital stay in colorectal surgery: results of a randomized controlled trial. Colorectal Dis. 2016;18(6):603-611.27273854
51 Alawadi ZM, Leal I, Phatak UR, . Facilitators and barriers of implementing enhanced recovery in colorectal surgery at a safety net hospital: A provider and patient perspective. Surgery. 2016;159(3):700-712.26435444
52 Ament SM, Gillissen F, Moser A, . Identification of promising strategies to sustain improvements in hospital practice: a qualitative case study. BMC Health Serv Res. 2014;14:641.25511582
53 Conn LG, McKenzie M, Pearsall EA, McLeod RS, Gotlib Conn L. Successful implementation of an enhanced recovery after surgery programme for elective colorectal surgery: a process evaluation of champions' experiences. Implement Sci. 2015;10(1):1-11.25567289
54 Lyon A, Solomon MJ, Harrison JD. A qualitative study assessing the barriers to implementation of enhanced recovery after surgery. World J Surg. 2014;38(6):1374-1380.24385194
55 Pearsall EA, Meghji Z, Pitzul KB, . A qualitative study to understand the barriers and enablers in implementing an enhanced recovery after surgery program. Ann Surg. 2015;261(1):92-96.24646564
56 Bernard H, Foss M. Patient experiences of enhanced recovery after surgery (ERAS). Br J Nurs. 2014;23(2):100-106.24464115
57 Taylor C, Burch J. Feedback on an enhanced recovery programme for colorectal surgery. Br J Nurs. 2011;20(5):286-290.21471876
58 Kahokehr A, Robertson P, Sammour T, Soop M, Hill AG. Perioperative care: a survey of New Zealand and Australian colorectal surgeons. Colorectal Dis. 2011;13(11):1308-1313.20958906
59 Keller DS, Delaney CP, Senagore AJ, Feldman LS, Force SST. Uptake of enhanced recovery practices by SAGES members: a survey. Surg Endosc. 2016;23:23.
60 Jeff A, Taylor C. Ward nurses' experience of enhanced recovery after surgery: a grounded theory approach. Gastrointest Nurs. 2014;12(4):23-31.
61 Chambers D, Paton F, Wilson P, . An overview and methodological assessment of systematic reviews and meta-analyses of enhanced recovery programmes in colorectal surgery. BMJ Open. 2014;4(5):e005014.
62 Paton F, Chambers D, Wilson P, . Effectiveness and implementation of enhanced recovery after surgery programmes: a rapid evidence synthesis. BMJ Open. 2014;4(7):e005015.
63 ERAS Compliance Group. The impact of enhanced recovery protocol compliance on elective colorectal cancer resection: results from an international registry. Ann Surg. 2015;261(6):1153-1159.25671587
64 Pecorelli N, Hershorn O, Baldini G, . Impact of adherence to care pathway interventions on recovery following bowel resection within an established enhanced recovery program. Surg Endosc. 2017;31(4):1760-1771.27538934
65 Pisarska M, Pedziwiatr M, Malczak P, . Do we really need the full compliance with ERAS protocol in laparoscopic colorectal surgery? A prospective cohort study. Int J Surg. 2016;36:377-382.27876677
66 Simpson JC, Moonesinghe SR, Grocott MPW, . Enhanced recovery from surgery in the UK: an audit of the enhanced recovery partnership programme 2009-2012. Br J Anaesth. 2015;115(4):560-568.25926312
67 Loftus TJ, Stelton S, Efaw BW, Bloomstone J. A system-wide enhanced recovery program focusing on two key process steps reduces complications and readmissions in patients undergoing bowel surgery. J Healthc Qual. 2017;39(3):129-135.28481841
68 Institute for Healthcare Improvement. Improvement Stories: What is a Bundle? http://www.ihi.org/resources/Pages/ImprovementStories/WhatIsaBundle.aspx.Accessed August 27, 2017.
69 Stone AB, Grant MC, Pio Roda C, . Implementation costs of an enhanced recovery after surgery program in the United States: a financial model and sensitivity analysis based on experiences at a quaternary academic medical center. J Am Coll Surg. 2016;222(3):219-225.26774492
70 McEvoy MD, Wanderer JP, King AB, . A perioperative consult service results in reduction in cost and length of stay for colorectal surgical patients: evidence from a healthcare redesign project. Perioper Med (Lond). 2016;5:3.26855773
71 Hubner M, Addor V, Slieker J, . The impact of an enhanced recovery pathway on nursing workload: A retrospective cohort study. Int J Surg. 2015;24(Pt A):45-50.26523495
72 Gillissen F, Ament SM, Maessen JM, . Sustainability of an enhanced recovery after surgery program (ERAS) in colonic surgery. World J Surg. 2015;39(2):526-533.25148885
73 Martin D, Roulin D, Addor V, Blanc C, Demartines N, Hubner M. Enhanced recovery implementation in colorectal surgery-temporary or persistent improvement? Langenbecks Arch Surg. 2016;401(8):1163-1169.27730406
74 Gramlich LM, Sheppard CE, Wasylak T, . Implementation of Enhanced Recovery After Surgery: a strategy to transform surgical care across a health system. Implement Sci. 2017;12(1):67.28526041
75 Liu VX, Rosas E, Hwang J, . Enhanced recovery after surgery program implementation in 2 surgical populations in an integrated health care delivery system. JAMA Surg. 2017:e171032.28492816
76 MacFie J. Enhanced recovery after surgery is obsolete. Dis Colon Rectum. 2016;59(10):1002-1003.27602933