# METHODS

## TOPIC DEVELOPMENT

The topic was nominated for review by William Gunnar, MD, JD, National Director of Surgery.

## SEARCH STRATEGY

We searched MEDLINE (Ovid) and the Cumulative Index to Nursing and Allied Health Literature (CINAHL) for English language publications from 2011 to July 2017. Search terms included terms used synonymously with ERAS (eg, fast track, multimodal, accelerated, enhanced) and terms for colorectal surgery (both open and laparoscopic). The search strategies are presented in Appendix B.

We obtained additional articles from reference lists of existing systematic reviews, reference lists of included studies, and suggestions from technical expert panel members.

## STUDY SELECTION

Abstracts identified in the literature searches were independently reviewed by 2 researchers. Full-text review of potentially eligible studies was completed by one researcher with input from investigators. We included:

1. Studies of adults undergoing elective colorectal surgery (any colorectal procedure, open or laparoscopic surgery),
2. For effectiveness of ERAS programs (KQ1-KQ4):
  a. randomized controlled trial (RCT) or controlled clinical trial (CCT)
  b. comparator is usual care or subset of ERAS components (as defined by study authors),
3. For barriers to and facilitators of implementation (KQ5):
  a. any study design providing qualitative data on barriers and facilitators
  b. study conducted in healthcare system relevant to VA.

We excluded:

1. Non-English language publications,
2. Studies that compared laparoscopic and open surgery within an enhanced recovery protocol,
3. Studies reporting outcomes before and after implementation of an enhanced recovery protocol (ie, pre-post or case series with historical controls design); we included controlled clinical trials if data collection was concurrent,
4. Trials of single component of enhanced recovery,
5. Studies that included post-operative components only (often referred to as “Post-operative Rehabilitation” or “Controlled Rehabilitation”).

## DATA ABSTRACTION

For each eligible study for KQ1 to KQ4, we created a table indicating the included ERAS components.^2,4^ We also noted which of the ERAS components were implemented as part of the usual care protocol.

We abstracted the following data onto evidence tables organized by type of surgery (open or laparoscopic):

1. Patient and study characteristics: study location (country); funding source; inclusion/exclusion criteria; length of follow-up; compliance with enhanced recovery protocol; patient age, gender, race/ethnicity, BMI or obesity status; comorbidity status; colorectal conditions; and surgical procedures
2. Outcomes (as defined above) for intervention and control groups

## QUALITY ASSESSMENT

Risk of bias of RCTs and CCTs was assessed using a modified Cochrane approach considering sequence generation, allocation, blinding, incomplete outcome reporting, and selective outcome reporting. Each study was rated as high, medium, low, or unclear risk of bias.^18^

## DATA SYNTHESIS

Tables were developed with studies pertaining to KQ1 and KQ2 noting outcomes reported by fidelity to enhanced recovery components (KQ3) or type of surgery (KQ4). If applicable, data for critical outcomes were pooled and analyzed using DerSimonian and Laird random-effects models^19^ in Cochrane Collaboration Review Manager software, Version 5.3 (The Nordic Cochrane Center, Copenhagen, Denmark). We calculated weighted mean differences (WMD) for length of stay and risk ratios (RR) for overall morbidity, all-cause mortality, readmissions, and surgical site infections. Peto odds ratios were applied when events were rare, such as mortality. Heterogeneity between studies was assessed by using the I^2^ test, with a I^2^ value greater than 50% considered substantial.^20^ If length of stay data were reported in medians, data were extracted from previous systematic reviews or converted to estimates of means and standard deviations based on methods outlined by Hozo.^21^

We qualitatively summarized findings for KQ5 (enhanced recovery barriers and facilitators).

## RATING THE BODY OF EVIDENCE

We evaluated the overall strength of evidence for our critical outcomes using a method developed by the Grading of Recommendations, Assessment, Development, and Evaluation (GRADE) group.(GRADEpro 2015 accessed at www.gradepro.org). The following domains were used to assess strength of evidence: 1) risk of bias; 2) consistency; 3) directness; and 4) precision. Strength of evidence ranges from high (indicating high confidence that the true effect lies close to that of the estimate of the effect) to very low (indicating very little confidence in the effect estimate and that the true effect is likely to be substantially different from the estimate of effect).

## PEER REVIEW

A draft version of this report was reviewed by content experts as well as clinical leadership. Reviewer comments and our responses are presented in Appendix C and the report was modified as needed.