# INTRODUCTION

Enhanced recovery after surgery (ERAS), also referred to as an enhanced recovery program, fast-track rehabilitation, multimodal management, or similar descriptors, is a multidisciplinary approach to perioperative care. A protocol of components related to preadmission, preoperative, intraoperative, and postoperative care is implemented with the goal of improving patient recovery, facilitating earlier discharge from the hospital, and potentially reducing health care costs without increasing complications or hospital readmissions.^1-3^ The protocol components may contribute to minimizing, and/or improving the response to, physiological stress associated with surgery.^1,2^

The ERAS Society has published guidelines for implementing an ERAS program for colorectal surgery.^2,4^ However, variation in the number and definition of protocol components contributes to difficulties in determining effectiveness. Little is known about implementation barriers and facilitators as well as components (or combinations of components) key for improved clinical outcomes. In addition, protocol compliance, when reported, may be measured by percentage of elements applied or completed without standardization across elements (timing, regimens, doses, etc).

Enhanced recovery protocols are not limited to colorectal surgery. ERAS Society guidelines are available for at least 15 procedures.^2^ However, given that the largest volume of evidence for comparative effectiveness of enhanced recovery and usual care protocols is available for colorectal surgery, we limit our review to studies of enhanced recovery for colorectal surgery.

Preliminary literature searches for topic refinement identified published systematic reviews on the topic. An overview of 13 systematic reviews published between 2011 and 2017 is presented in Appendix A.^5-17^ Three focused only on laparoscopic surgery.^11,15,16^ None of the existing reviews reported on subgroups based on surgical approach (open or laparoscopic surgery) or colorectal condition. While several noted the enhanced recovery protocol components from the included studies, the standard care protocols were not documented. Only one systematic review formally rated the overall quality of evidence.^17^ None commented on barriers or facilitators to implementation of an enhanced recovery program.

The defining components of an enhanced recovery program for colorectal surgery have been revised over time^2^ and new trials have been published since the search dates of the existing reviews. We provide an updated review of randomized controlled trials (RCTs) and controlled clinical trials (CCTs), looking at comparative effectiveness and harms overall and by type of surgery, colorectal condition, and fidelity to an enhanced recovery protocol. We also review barriers and facilitators to implementation and provide a contextual discussion of compliance and outcomes.

With input from the topic nominator and a technical expert panel, we developed the following analytic framework (Figure 1); population, intervention, comparator, outcomes (PICO); and key questions.

Figure 1 Analytic Framework

a Consider subgroups based on comorbidity status, mobility status, frailty index, age, patient size, right vs left side, laparoscopic vs open procedure, type of surgery (KQ4)

## PICO

[underlined: Population:] Adults (18 and over) undergoing elective colorectal surgery

[underlined: Intervention:] Enhanced recovery program (as defined by study authors)

[underlined: Comparator:] Usual care or subset of enhanced recovery components not meeting author definition of a full enhanced recovery program

[underlined: Outcomes:]

Final Health Outcomes: Length of stay (initial stay, total); overall morbidity; mortality; readmission rate; ileus; clinically important difference in pain scores; and clinically meaningful changes in quality of life

Intermediate: Gastrointestinal function (time to oral feeding, bowel function, nausea), intravenous fluid administration, mobilization, pain scale scores

Harms: Surgical complications (infection, anastomotic leakage), non-surgical complications (cardiovascular, respiratory, urinary tract infection), need for re-operation, bleeding, Foley catheter re-insertion and complications, aspiration pneumonia, readmission

## Key Questions

KQ1: What is the comparative effectiveness of ERAS versus usual care or a subset of ERAS components for adults undergoing elective colorectal surgery?

KQ2: What are the harms of ERAS versus usual care or a subset of ERAS components for adults undergoing elective colorectal surgery?

KQ3: Do comparative effectiveness and harms vary by fidelity to ERAS components?

KQ4: Do comparative effectiveness and harms vary by type of, and clinical conditions for, colorectal surgery (eg, anatomical site, laparoscopic versus open surgery, reasons for open surgery, etc)?

KQ5: What are the barriers to and facilitators of implementation of ERAS programs?