# APPENDIX G POOLED ANALYSES BY PROCEDURE AND COLORECTAL CONDITION

Figure 1 Length of Stay by Procedure^a^ a Excludes Forsmo 2016^50^ (mixed open and laparoscopic surgery)

Figure 2 Length of Stay by Condition

Figure 3 Mortality by Procedure^a^ a Excludes Forsmo 2016^50^ (mixed open and laparoscopic surgery)

Figure 4 Mortality by Condition

Figure 5 Morbidity by Procedure^a^ a Excludes Forsmo 2016^50^ (mixed open and laparoscopic surgery)

Figure 6 Morbidity by Condition

Figure 7 Readmissions by Procedure^a^ a Excludes Forsmo 2016^50^ (mixed open and laparoscopic surgery)

Figure 8 Readmissions by Condition

Figure 9 Surgical Site Infections by Procedure^a^ a Excludes Forsmo 2016^50^ (mixed open and laparoscopic surgery)

Figure 10 Surgical Site Infections by Condition