# APPENDIX F EVIDENCE PROFILE FOR ERAS COMPARED TO CONTROL FOR COLORECTAL SURGERIES

Quality assessment | | | | | | | N[underlined: o] of patients | | Effect | | Quality
N[underlined: o] of studies | Study design | Risk of bias | Inconsistency | Indirectness | Imprecision | Other considerations | ERAS | Control | Relative (95% CI) | Absolute (95% CI) | Quality
Length of stay
21 | randomized trials | Serious ^a^ | serious ^b^ | not serious | not serious | Strong association | 1463 | 1470 | - | MD 2.4 days lower (3.1 lower to 1.8 lower) | ⊕⊕⊕○ MODERATE
Mortality
22 | randomized trials | Serious ^a^ | not serious | not serious | serious ^c^ | none | 16/1619 (1.0%) | 9/1636 (0.6%) | OR 1.79 (0.81 to 3.95) | 4 more per 1,000 (from 1 fewer to 16 more) | ⊕⊕○○ LOW
Perioperative morbidity
19 | randomized trials | Serious ^a^ | not serious | not serious | not serious | none | 299/1456 (20.5%) | 426/1463 (29.1%) | RR 0.66 (0.54 to 0.80) | 99 fewer per 1,000 (from 58 fewer to 134 fewer) | ⊕⊕⊕○ MODERATE
Readmissions
19 | randomized trials | Serious ^a^ | not serious | not serious | serious ^d^ | none | 73/1196 (6.1%) | 84/1319 (6.4%) | RR 1.11 (0.82 to 1.50) | 7 more per 1,000 (from 11 fewer to 32 more) | ⊕⊕○○ LOW
Surgical site infection
17 | randomized trials | Serious ^a^ | not serious | not serious | serious ^d^ | none | 50/1443 (3.5%) | 69/1437 (4.8%) | RR 0.75 (0.52 to 1.07) | 12 fewer per 1,000 (from 3 more to 23 fewer) | ⊕⊕○○ LOW

CI: Confidence interval; MD: Mean difference; RR: Risk ratio; OR: Odds ratio

Explanations

a Mostly moderate, high, or unclear RoB

b I-square indicated substantial statistical heterogeneity

c Wide confidence intervals and very few events

d Wide confidence intervals