# APPENDIX E ERAS AND USUAL CARE COMPONENTS

Table 1 ERAS and Standard Care Protocol Components - Open Surgery Studies (SEE Appendix E Table 2 for Gouvas 2012, Wang 2012 J Gast Surg, and Vlug 2011)

Author, Year: Feng 2016^23^ | Reason for Surgery: Colorectal Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use)
INTRAOPERATIVE | Control of body temperature | ✓
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Pappalardo 2016^31^ (Standard Protocol Not Specified) | Reason for Surgery: Rectal Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep)
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery)
PREOPERATIVE | Carbohydrate treatment
PREOPERATIVE | Thrombosis prophylaxis | ✓
PREOPERATIVE | Infection prophylaxis including skin preparation with chlorhexidine-alcohol | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ (epidural)
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization
POSTOPERATIVE | Early intake of oral fluids and solids
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Jia 2014^27^ | Reason for Surgery: Colon (49%) or Rectal (51%) Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery)
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Nanavati 2014^30^ | Reason for Surgery: Colorectal Procedures (42% Ileostomal Closure, 17% Colostoma Closure); 7% Laparoscopic
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery)
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis | ✓
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques | ✓
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓ | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Ren 2012^32^ | Reason for Surgery: Colorectal Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis | ✓ | ✓
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature | ✓
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓ (early removal) | ✓ (early removal)
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents | ✓
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Yang 2012^37^ | Reason for Surgery: Colorectal Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep)
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓ | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ (avoid long-acting opiods) | ✓ (avoid long-acting opiods)
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓ (fluid restriction) | ✓ (fluid restriction)
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓ | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature | ✓ | ✓
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control | ✓
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓ | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Wang 2011^36^ | Reason for Surgery: Colon (65%) or Rectal (35%) Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use) | ✓
INTRAOPERATIVE | Minimal invasive surgical techniques | ✓
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Ionescu 2009^26^ | Reason for Surgery: Rectosigmoid (58%) or Colon (42%) Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓ | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓ | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge | ✓ | ✓

Author, Year: Muller 2009^29^ | Reason for Surgery: 87% Colon Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓ | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓ (4 hrs) | ✓ (4 hrs)
PREOPERATIVE | Carbohydrate treatment
PREOPERATIVE | Thrombosis prophylaxis | ✓ | ✓
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓ | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓ | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓ | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓ | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓ | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓ | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Šerclová 2009^33^ | Reason for Surgery: 78% Crohn's, 9% Ulcerative Colitis, 7% Cancer, 6% Other, only ASA I-II, average age 35
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Khoo 2007^28^ | Reason for Surgery: Colon (67%) and Rectal (33%) Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep)
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓ (3 hrs) | ✓ (3 hrs)
PREOPERATIVE | Carbohydrate treatment
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis | ✓
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents | ✓
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Gatt 2005^24^ | Reason for Surgery: 69% Colon Cancer, 31% Other (Colon)
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓ (3 hrs)
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓ | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Anderson 2003^22^ | Reason for Surgery: 72% Colon Cancer; 28% Other (Colon)
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓ | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Table 2 ERAS and Standard Care Protocol Components – Laparoscopic Surgery Studies

Author, Year: Ota 2017^42^ (Standard Care at surgeon's discretion; many components [*] implemented) | Reason for Surgery: Colon or Rectosigmoid Cancer (90% Laparoscopic Surgery)
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓^a^
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery)
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis | ✓
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓ | *
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques | ✓ (>90%) laparoscopic) | ✓ (>90% laparoscopic)
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ (epidural anesthesia) | * (epidural anesthesia)
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓ | *
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓ | *
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓ | *
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓ | *
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents | ✓ (gum, laxative) | * (laxative)
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Scioscia 2017^43^ | Reason for Surgery: Bowel Endometriosis
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓ (low residue diet)
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery)
PREOPERATIVE | Carbohydrate treatment
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques | ✓ (laparoscopic) | ✓ (laparoscopic)
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Mari 2016^40^ | Reason for Surgery: Major Colorectal Surgery (75% Cancer, 25% Diverticular Disease)
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques | ✓ (laparoscopic) | ✓ (laparoscopic)
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Wang 2015^45^ (same protocol as Ren 2012^32^ except minimally invasive) | Reason for Surgery: Colon Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis | ✓ | ✓
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques | ✓ | ✓
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature | ✓
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓ (early removal) | ✓ (early removal)
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents | ✓
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Feng 2014^38^ | Reason for Surgery: Rectal Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery)
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques | ✓ | ✓
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use)
INTRAOPERATIVE | Control of body temperature | ✓
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Mari 2014^41^ | Reason for Surgery: 69% Colon Cancer, 31% Diverticular Disease
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep)
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery)
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓ | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques | ✓ | ✓
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature | ✓ | ✓
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓ | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Gouvas 2012^25^ | Reason for Surgery (Open and Laparoscopic): Rectal Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep)
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques (laparoscopic arms only) | ✓ | ✓
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓ (removal)
INTRAOPERATIVE | Control of body temperature | ✓
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge | ✓

Author, Year: Wang 2012^35^ and Wang 2012^44^ | Reason for Surgery: Colon Cancer NOTE: Wang 2012^35^ – Open and Laparoscopic
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques (laparoscopic arms only) | ✓ | ✓
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Wang 2012^46^ | Reason for Surgery: Colorectal Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery)
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use)
INTRAOPERATIVE | Minimal invasive surgical techniques | ✓ | ✓
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓ (removal)
INTRAOPERATIVE | Control of body temperature
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents | ✓
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge

Author, Year: Vlug 2011^34^ | Reason for Surgery (Open and Laparoscopic): Colon Cancer
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep) | ✓ | ✓
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol
PREOPERATIVE | Nausea and vomiting prophylaxis | ✓
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use) | ✓
INTRAOPERATIVE | Minimal invasive surgical techniques (laparoscopic arms only) | ✓ | ✓
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | ✓ (and general anesthesia) | ✓ (and general anesthesia)
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓ | ✓
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓ | ✓
INTRAOPERATIVE | Control of body temperature | ✓ | ✓
POSTOPERATIVE | Early mobilization | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents | ✓
POSTOPERATIVE | Protein and energy-rich nutritional supplements | ✓
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓ | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting

a not used for right hemicolectomy or transverse colectomy

Table 3 ERAS and Standard Care Protocol Components - Open and Laparoscopic Surgery Studies

Author, Year: Forsmo 2016^50^ | Reason for Surgery: Colorectal Surgery (Malignant [79%] or Benign [21%]) (Open [60%] or Laparoscopic [40%] Surgery)
Phases | ERAS Components | ERAS Protocol | Standard Care Protocol
PREADMISSION | Smoking/alcohol cessation
PREADMISSION | Nutritional screening/support
PREADMISSION | Medical optimization of chronic disease
PREOPERATIVE | Structured information/patient and caretaker engagement | ✓
PREOPERATIVE | Bowel preparation (no routine use of mechanical bowel prep)
PREOPERATIVE | Pre-operative fasting (clear fluids to 2 hours and solids to 6 hours before surgery) | ✓ | ✓ (fluids to 2 hrs)
PREOPERATIVE | Carbohydrate treatment | ✓
PREOPERATIVE | Thrombosis prophylaxis | ✓ | ✓
PREOPERATIVE | Infection prophylaxis and/or skin preparation with chlorhexidine-alcohol | ✓ | ✓
PREOPERATIVE | Nausea and vomiting prophylaxis
PREOPERATIVE | Pre-anesthetic sedative medication (no routine use) | ✓
INTRAOPERATIVE | Minimal invasive surgical techniques
INTRAOPERATIVE | Standardized anesthesia protocol – may use thoracic epidural blocks with local anesthetics and low-dose opioids for open surgery and spinal analgesia or patient-controlled morphine as alternative to thoracic epidural for laparoscopic surgery | unclear | unclear
INTRAOPERATIVE | Maintain fluid balance; vasopressors for blood pressure control | ✓
INTRAOPERATIVE | Restrictive use of surgical site drains | ✓ (no drain for colon resection) | ✓ (no drain for colon resection)
INTRAOPERATIVE | Remove nasogastric tubes before reversal of anesthesia (and no routine use) | ✓ | ✓
INTRAOPERATIVE | Control of body temperature | ✓ | ✓
POSTOPERATIVE | Early mobilization | ✓ (enforced) | ✓
POSTOPERATIVE | Early intake of oral fluids and solids | ✓ (enforced) | ✓
POSTOPERATIVE | Early removal of urinary catheters and intravenous fluids | ✓
POSTOPERATIVE | Chewing gum, laxatives, peripheral opioid-blocking agents | ✓
POSTOPERATIVE | Protein and energy-rich nutritional supplements
POSTOPERATIVE | Glucose control
POSTOPERATIVE | Multimodal approach to opioid-sparing pain control – consider thoracic epidural analgesia (open surgery) or spinal analgesia (laparoscopic surgery); also NSAIDS and paracetamol | ✓
POSTOPERATIVE | Multimodal approach to control of nausea and vomiting
POSTOPERATIVE | Prepare for early discharge