# Appendix D EVIDENCE TABLES

Table 1 Study Characteristics

Author, year Country Funding Source | Inclusion/Exclusion Criteria | Intervention (n) Control (n) Follow-up | Demographics | Risk of Bias
Open Surgery Studies
Feng 2016^23^ China Government funding | Inclusion: age 18-70 years; histological diagnosis of colorectal cancer; no radiotherapy or chemotherapy treatment; no severe diarrhea, liver and kidney function failure, or cardiopulmonary insufficiency; ASA I-III; BMI 18.5-30; abdominal CT with no obvious lymph node or distant metastasis Exclusion: history of abdominal surgery; endocrine or immune system dysfunction (eg, diabetes, thyroid disease, multiple sclerosis, rheumatoid arthritis); recent blood transfusions; preoperative treatment with opioids, hormones, non-steroidal anti-inflammatory drugs, or other immunomodulatory substances; contraindications for epidural anesthesia | Intervention: fast-track surgery (n=121) Control: traditional care (n=120) Follow-up: 30 days Compliance: NR | N=241 (data for 230) Colorectal conditions (%): 44 colon, 56 rectum Procedures (%): NR Age (mean): 58 Gender (% male): 56 BMI: 24 Comorbidity status: ASA I (27), ASA II (50), ASA III (23) | Sequence generation: NR Allocation concealment: unclear Blinding: unclear; treatment team and patient/family not blinded; data collectors were not involved in patient management Incomplete outcome data: adequate (5% excluded from analysis due to non-compliance, ostomy surgery) Selective outcome reporting: no Risk of bias: medium
Pappalardo 2016^31^ Italy No funding indicated | Inclusion: extraperitoneal tumor location (within 12 cm above anal verge); cT2-T4 tumors with or without positive lymph nodes, elective procedure; neoadjuvant therapy where indicated Exclusion: tumor >12 cm above anal verge, cT1 or M1, urgent procedure, ASA >3, operated on with abdominoperineal resection or Hartmann's procedure, refusing neoadjuvant therapy where indicated, refusing or unable to follow fast-track protocol, coagulation disorder contraindicating epidural catheter insertion NOTE: 56% of fast-track and 52% of traditional care groups received neoadjuvant therapy | Intervention: fast-track protocol (n=25) Control: traditional care (n=25) Follow-up: 30 days Compliance: NR | N=50 Colorectal conditions (%): 100% rectal cancer Procedures (%): anterior resection (62), ultra-low anterior resection (36) Castrini technique (4) Age (mean): 67 Gender (% male): 52 BMI: 38% <25; 20% >30 Comorbidity status: ASA I (10), ASA II (42), ASA III (48) | Sequence generation: NR Allocation concealment: NR Blinding: adequate (outcome assessors) Incomplete outcome data: yes (mean data not reported) Selective outcome reporting: yes (data not reported at time points identified in methods) Risk of bias: high
Jia 2014^27^ China No funding indicated | Inclusion: elderly patients with colorectal carcinoma admitted for open curative resection Exclusion: history of dementia, Parkinson's disease, alcohol intake of ≥250 g/day, long-term use of sleeping pills or anxiolytics, and those who received anesthesia within the past 30 days | Intervention: fast-track surgery (n=120) Control: traditional care (n=120) Follow-up: NR, perioperative period Compliance: NR | N=240 (all elderly, ages 70-88) (data for 233) Colorectal conditions (%): colon cancer (49); rectal cancer (51) Procedures (%): colectomy (45); Dixon (32), Miles (23) Age (mean): 75 Gender (% male): 63 BMI: NR Comorbidity status: NR | Sequence generation: adequate Allocation concealment: NR Blinding: NR Incomplete outcome data: 3% (n=7, including 3 who went to ICU) not included in analyses Selective outcome reporting: no Risk of bias: medium
Nanavati 2014^30^ India No funding indicated | Inclusion: age 16-66 years, undergoing anastomosis anywhere distal to the ileum Exclusion: uncontrolled comorbid conditions (eg, diabetes mellitus, hypertension) and emergency bowel surgeries | Intervention: fast-track peri-operative care (n=30) Control: traditional perioperative care (n=30) Follow-up: 30 days Compliance: NR | N=60 Colorectal conditions (%): ileostomy closure 42 colostomy closure 28 abdominal pain 13 ileocolostomy closure 8 other 9 Age (mean): 34 Gender (% male): 53 BMI: NR Comorbidity status: NR | Sequence generation: NR Allocation concealment: unclear Blinding: NR Incomplete outcome data: no loss to follow-up Selective outcome reporting: no Risk of bias: unclear
Gouvas 2012^25^ CCT Greece No funding indicated 2 X 2 study (open vs laparoscopic and fast track vs usual care) | Inclusion: diagnosed with adenocarcinoma of lower 2/3 of rectum Exclusion: emergency cases, tumor other than adenocarcinoma, distant metastases, neuromuscular disability, unsuitable for epidural anesthesia; ASA IV, refusal to consent to fast-track care or laparoscopy, different operation performed than originally scheduled | Intervention: open surgery combined with fast track (n=36) Control: open surgery usual care (n=45) Follow-up: 30 days Compliance: NR | N=81 Colorectal conditions (%): rectal cancer (100) Age (mean): 64 Gender (% male): 67 (fast track 53% vs 78% usual care, P=.001 across groups) BMI: 28 Comorbidity status (%): ASA I (42); ASA II (46), ASA III (12) | Sequence generation: NA (CCT) Allocation concealment: NA, grouped according to surgeon's preference Blinding: NR Incomplete outcome data: no Selective outcome reporting: no Risk of bias: high
Ren 2011^32^ China Government funding | Inclusion: age 20-80 years, single colorectal lesion, medically eligible for radical colorectal surgery Exclusion: emergency surgery, synchronous resection of other organs, past abdominopelvic surgical history, affliction with a disease that would affect recovery | Intervention: ERAS group (n=299) Control: usual care (n=298) Follow-up: 30 days Compliance: NR | N= 676 (Data for 597) Procedures (%): right hemicolectomy (28), left hemicolectomy (6), low anterior resection (44), abdominoperineal resection (13), other (9) Age (median): 59 (ERAS), 61 (control) Gender (% male): 62 BMI (median): 22.5 Comorbidity status: ASA (mean) Control 1.4 (0.4) ERAS 1.4 (0.3) | Sequence generation: adequate Allocation concealment: NR Blinding: adequate (outcomes assessment) Incomplete outcome data: 0% (79 were randomized but then found to not meet inclusion criteria) Selective outcome reporting: no Risk of bias: low
Wang 2012^35^ China No funding indicated 2 X 2 study (open vs laparoscopic and fast track vs usual care) | Inclusion: no disease of immune system, no pre-operative radiotherapy or chemotherapy, no history of operation on abdominal and distant metastases, ASA score I–III, and self-care function prior to hospitalization Exclusion: association with other organ resection, conversion from laparoscopic operation to laparotomy, inability to place an epidural catheter, inability to infuse drugs, need for a stoma, and emergency operation | Intervention: open surgery combined with fast track (n=42) Control: open surgery usual care (n=44) Follow-up: 30 days Compliance: NR | N=86 (data for 83) Colorectal conditions (%): colon cancer 100 Age (median): 55 (fast track), 57 (usual care) Gender (% male): 59 BMI: 22.5 Comorbidity status (%): ASA I (40), ASA II (46), ASA III (14) | Sequence generation: NR Allocation concealment: adequate Blinding: NR Incomplete outcome data: 3% (n=3) excluded from analyses Selective outcome reporting: no Risk of bias: unclear
Yang 2012^37^ China No funding indicated | Inclusion: age 18-80, diagnosed with colorectal carcinoma, no preoperative chemotherapy or radiotherapy, ASA score I-II, BMI 17.5-27.5, preoperative serum albumin ≥30g/L, elective open colorectal resection with tracheal intubation and general anesthesia Exclusion: immune-related disease, primary diabetes mellitus or impaired glucose tolerance, hiatus hernia, gastroesophageal reflux disease (GERD), pregnancy, bowel obstruction, difficult airway access, drug intake that may affect bowel movement and function, failure of thoracic epidural catheter insertion, intraoperative blood transfusion, stoma requirement, unresectable carcinoma | Intervention: fast-track group (n=35) Control: conventional care (n=35) Follow-up: 30 days Compliance: Use of checklists to maintain compliance. Did not report results of checklists | N= 70 (data for 62) Procedures (%): right hemicolectomy (21), left hemicolectomy (8); sigmoidectomy (21), Dixon operation (50) Age (median): 57 (fast track), 60 (usual care) Gender (% male): 68 BMI (median): 22 Comorbidity status: NR | Sequence generation: adequate Allocation concealment: adequate Blinding: adequate (outcome assessment) Incomplete outcome data: 11% (n=8) not included in analysis Selective outcome reporting: no Risk of bias: low
Vlug 2011^34^ LAFA-study The Netherlands (multisite) Industry 2 X 2 study (open vs laparoscopic and fast track vs usual care) | Inclusion: ages 40-80 years; ASA I, II, or III; elective segmental colectomy for histologically confirmed adenocarcinoma or adenoma; without evidence of metastatic disease Exclusion: prior midline laparotomy, unavailability of a laparoscopic surgeon, emergency surgery, or a planned stoma | Intervention: open surgery combined with fast track (n=103) Control: open surgery usual care (n=108) Follow-up: 30 days Compliance: 15 components monitored for compliance, 11.1 of 15 components successfully applied per patient in fast-track group;.5.8 components of fast track successfully applied per patient in usual care group | N=211 (data for 191) Colorectal conditions (%): colon cancer and benign disease 100 Procedures (%): right colectomy (45), left colectomy (55) Age (mean): 66 Gender (% male): 59 BMI: 26 Comorbidity status (%): ASA I or II (79), III (21) | Sequence generation: NR Allocation concealment: adequate Blinding: patients and medical staff blinded for surgical approach (laparoscopic vs open) until day of discharge Incomplete outcome data: 10% (n=20) were excluded from analyses (9 of 20 [45%] withdrew consent) Selective outcome reporting: no Risk of bias: medium
Wang 2011^36^ China Social Development Fund | Inclusion: NR Exclusion: non-selective admission, preoperative distant metastases, stoma, emergency situation, scheduled total colectomy or abdominoperineal resection, contraindications for epidural anesthesia or early ambulation | Intervention: fast-track rehabilitation (n=106) Control: conventional care (n=104) Follow-up: 30 days Compliance: NR | N=230 (data for 210) Colorectal condition (s)(%): colon (65), rectum (35) Procedures (%): right hemicolectomy (26), left hemicolectomy (20), sigmoid colectomy (29), anterior resection (25) Age (median): 57 (fast track), 55 (conventional care) Gender (% male): 60 BMI: NR Comorbidity status (%): ASA I (28), ASA II (55), ASA III (17) | Sequence generation: NR Allocation concealment: NR Blinding: NR Incomplete outcome data: 0% Selective outcome reporting: no Risk of bias: unclear
Ionescu 2009^26^ Romania No funding indicated | Inclusion: ASA score I-III, admitted to hospital for elective open colorectal surgery for neoplasm Exclusion: previous abdominal surgery, extensive neoplasm, severe malnutrition, surgery for complications (bowel obstruction), and palliative surgical procedures | Intervention: fast-track protocol (n=48) Control: conventional care program (n=48) Follow-up: NR (perioperative; patients asked to mention inclusion in study in case of readmission) Compliance: NR | N=96 (Data for N=96) Colorectal conditions (%): rectosigmoid (58); colon (42) Procedures: right hemicolectomy (29). left hemicolectomy (11), segmental colonic resection (1), rectosigmoidian resection (58) Age (mean): 62 Gender (% male): 64 BMI: NR Comorbidity status (%): ASA I (52), ASA II (45), ASA III (3) Subgroups noted ^a^: None | Sequence generation: adequate Allocation concealment: adequate Blinding: NR Incomplete outcome data: 0% Selective outcome reporting: no Risk of bias: low
Muller 2009^29^ Switzerland No funding indicated | Inclusion: age >18, elective open colonic resection with a primary anastomosis Exclusion: emergency situations, contraindication to epidural anesthesia, scheduled total colectomy or rectum resection, preoperatively immobile | Intervention: fast-track program (n=76) Control: standard care (n=75) Follow-up: 30 days Compliance: adherence reported for intraoperative intravenous intake, first 24-hour intravenous intake, effective epidural analgesia, mobilization time day 1, and oral nutrition day 1 and day 4 NOTE: study stopped prematurely after reaching significant difference for primary endpoint (total complications to 30 days after surgery) | N= 156 (data for 151) Procedures (%): sigmoid resection or left hemicolectomy (67), resection of transverse colon (1), right hemicolectomy (32) Age (median): 62 (fast track), 59 (standard care) (P=.04) Gender (% male): 51 BMI (median): 24 (fast track), 26 (standard care) Comorbidity status (%): ASA I (3), ASA II (69); ASA III (28) | Sequence generation: NR Allocation concealment: unclear Blinding: no Incomplete outcome data: 3% (n=5) not included in analysis Selective outcome reporting: did not report data from BADL (need for personal care) nor IADL (ability to perform physical activities) Risk of bias: high
Šerclová 2009^33^ Czech Republic Government | Inclusion: age 18-70 years, ASA score between I or II, open intestinal resection Exclusion: pelvic radiation, multi-organ resections, cancer, pregnant women | Intervention: fast-track group (n=53) Control: conventional care (n=52) Follow-up: 30 days Compliance: NR | N= 105 (data for 103) Colorectal conditions (%): Crohn's disease (78), ulcerative colitis (9), familial adenomatous polyposis (5), carcinoma (7), other (2) Procedures (%): simple bowel resection (54), multiple (25), resection and stomy (20) Age (mean): 36 Gender (% male): 50 BMI (median): NR Comorbidity status (%): NR | Sequence generation: adequate Allocation concealment: adequate Blinding: NR Incomplete outcome data: 2% (n=2) not included in analysis Selective outcome reporting: no Risk of bias: low
Khoo 2007^28^ UK No funding indicated | Inclusion: elective surgery for colorectal cancer. Exclusion: unable to mobilize independently over 100 meters at preoperative assessment, contraindications to thoracic epidurals, preexisting clinical depression, palliation, a joint operation involving another surgical specialty | Intervention: multimodal package (n=35) Control: usual care (n=35) Follow-up: 10-14 days Compliance: Both arms were protocol-driven, with checklists | N=81 (data for 70) Colorectal conditions (%): colon cancer (67), rectal cancer (33) Age (median): 69 (multimodal), 73 (usual care) Gender (% male): 39 BMI: NR Comorbidity status (%): ASA I (11), ASA II (74), ASA III (14) | Sequence generation: adequate Allocation concealment: adequate (telephone) Blinding: NR Incomplete outcome data: 14% (n=11 withdrawn, 7 due to metastatic disease 3 withdrew consent) Selective outcome reporting: no Risk of bias: medium
Gatt 2005^24^ UK No funding indicated | Inclusion: requiring elective colorectal surgery, living independently at home Exclusion: age<18 years, pregnancy, intolerance to probiotics and/or preantibiotics, contraindication to one or more optimization strategy, contraindications to early postoperative discharge, prescribed medications that may independently prolong hospital stay (eg, anticoagulants), advanced malignancy on preoperative assessment, palliative or emergency surgery, failure to perform colonic or rectal resection | Intervention: multimodal optimization (n=19) Control: usual care (n=20) Follow-up: 30 days Compliance: NR | N=39 Colorectal conditions (%): malignant disease (69) Procedures (%): right hemicolectomy (28), left hemicolectomy (5), anterior resection (38), sigmoid colectomy (5), subtotal colectomy (8), abdominoperineal resection (5), other (11) Age (median): 67 (both groups) Gender (% male): 59 BMI: medians 24 (multimodal), 27 (usual care) Comorbidity status: POSSUM score (medians) 28 (multimodal), 32 (usual care); ASA (median)=2 (both groups) | Sequence generation: unclear Allocation concealment: unclear Blinding: no Incomplete outcome data: all included in the analyses Selective outcome reporting: no Risk of bias: unclear
Anderson 2003^22^ UK No funding indicated | Inclusion: lived independently at home and required left or right hemicolectomy Exclusion: NR | Intervention: multimodal optimization (n=14) Control: usual care (n=11) Follow-up: 30 days Compliance: NR | N=25 Colorectal conditions (%): malignant disease 72% Age (medians): 64 (multimodal), 67 (usual care) Gender (% male): 44 BMI: medians 24 (multimodal), 26 (usual care) Comorbidity status: POSSUM score (median) 26 (both groups); ASA I/II 92%, III 8% | Sequence generation: NR Allocation concealment: unclear Blinding: no Incomplete outcome data: no Selective outcome reporting: no Risk of bias: unclear
Laparoscopic Studies
Ota 2017^42^ Japan CCT No funding indicated | Inclusion: ASA grade I or II, elective surgery for colonic or rectosigmoid cancer in 1 of 6 hospitals, white blood cell count ≥3000/μL, platelet count ≥100,000/μL, serum aspartate aminotransferase or alamine aminotransferase level ≤100IU/μL, total bilirubin ≤2mg/dl, serum creatinine ≤1.5 mg/dl Exclusion: emergency surgery, bowel obstruction preoperatively, routine use of steroids, history of cancer treatment using irradiation or chemotherapy, previous laparotomy other than for appendectomy, oophorectomy, or caesarean section | Intervention: enhanced recovery after surgery (n=159) Control: conventional perioperative care (n=161) Follow-up: 30 days Compliance: average rate of compliance with each ERAS intervention in ERAS group was 85%; over 50% of ERAS components were implemented in conventional care group; improved adherence to ERAS protocol significantly associated with reduced length of stay (P=.01) but not overall complications (P=.29) | N=320 Colorectal locations (%): cecum (16), ascending (29), transverse (12), descending (7), sigmoid (29), rectosigmoid (14) Age (medians): 69 (ERAS), 68 (conventional care) Gender (% male): 50 BMI: NR Comorbidity status (%): ASA I (37), ASA II (63) | Sequence generation: NA, not randomized Allocation concealment: NA, grouped according to hospital where operation was performed Blinding: NR Incomplete outcome data: no Selective outcome reporting: no Risk of bias: high
Scioscia 2017^43^ Italy No funding indicated | Inclusion: age >18 years, preoperative evidence of bowel endometriosis (imaging or other), primary laparoscopic approach Exclusion: surgery for reasons other than endometriosis, laparotomy or vaginal approach, endometriosis without bowel involvement, did not consent to intestinal surgery | Intervention: fast-track care (n=62) Control: conventional care (n=165) NOTE: 1:3 ratio for randomization Follow-up: 30 days Compliance: NR | N=227 Colorectal conditions (%): bowel endometriosis (100) Procedure (%): bowel segmental resection (86) Age (mean): 35 Gender (% male): 0 BMI: 22 Comorbidity status: Barthel index (median) 100 for both groups (complete independence) | Sequence generation: unclear; based on scheduled day of surgery Allocation concealment: unclear; day of surgery assigned by secretary blind to study Blinding: surgeons and anesthetists blinded to the group assigned to them Incomplete outcome data: adequate (no loss to follow-up) Selective outcome reporting: no Risk of bias: medium
Mari 2016^40^ Italy No funding indicated | Inclusion: indication for major colorectal surgery, age 18-80 years, ASA I to III, autonomous for mobilization and walking, eligible for laparoscopic technique Exclusion: no additional criteria reported | Intervention: ERAS (n=70) Control: standard care (n=70) Follow-up: 5 days Compliance: 90% accordance with ERAS guidelines | N=140 Colorectal conditions (%): diverticulitis (25), adenocarcinoma (75) (left 43%, right 31%, rectal 26%) Age (mean): 66 Gender (% male): 53 BMI: 27 Comorbidity status (%): ASA I (23), ASA II (64), ASA III (14) | Sequence generation: adequate Allocation concealment: unclear Blinding: unclear Incomplete outcome data: adequate; ITT analysis, 4% (n=5) from ERAS group discharged before day 5 blood sample Selective outcome reporting: no Risk of bias: medium
Wang 2015^45^ China CCT No funding indicated | Inclusion: underwent colonic surgery (radical resection of colonic cancer) by one surgical group (July 2012-Oct 2013) Exclusion: NR | Intervention: ERAS program (n=57) Control: usual care (n=60) Follow-up: 28 days Compliance: NR | N=117 Colorectal conditions (%): cancer 100 (right side 79%, left side 21%) Age (mean): 59 Gender (% male): 47 BMI: 24 Comorbidity status: ASA score=1 72%, ASA score=2 28% | Sequence generation: NA (CCT) Allocation concealment: NA (CCT) Blinding: self-administered questionnaire Incomplete outcome data: 96% response rate overall Selective outcome reporting: no Risk of bias: medium
Feng 2014^38^ China National Natural Scientific Foundation of China Laparoscopic (94%) | Inclusion: age 18-75 years; diagnosed with rectal cancer based on clinical symptoms, imaging, and pathological evidence, with no findings of tumor invasion to adjacent organs, local, or distal metastasis; no preoperative radiotherapy or chemotherapy; ASA physical status I or II Exclusion: pregnant or lactating women; primary diabetes; complete bowel obstruction; severe cardiopulmonary or immune related diseases; human immunodeficiency virus infection or acquired immunodeficiency syndrome related diseases; palliative or emergency operation; combined resection of spleen or pancreas; severe adverse events (eg, cerebrovascular accident or massive hemorrhage); history of radio-chemotherapy | Intervention: fast-track surgery (n=60) Control: usual care (n=60) Follow-up: 4 weeks Compliance: NR | N=120 (data for n=116) Colorectal condition (s): rectal cancer Procedure: radial anterior resection with TME Age (mean): 55 Gender (% male): 66 BMI: 22 Comorbidity status (%): ASA I (4), ASA II (96) | Sequence generation: adequate Allocation concealment: adequate Blinding: adequate (outcomes assessment) Incomplete outcome data: 3% (n=4, unresectable tumor and withdrawal of consent) not included in analyses Selective outcome reporting: no Risk of bias: low
Mari 2014^41^ Italy No fundning indicated | Inclusion: age 18-85 years, total laparoscopic high anterior resection, ASA score I-III, BMI <30, no intestinal diversion Exclusion: NR | Intervention: fast-track program (n=26) Control: usual care (n=26) Follow-up: 30 days Compliance: NR | N=52 (data for 50) Colorectal condition (s) (%): colon cancer (69), diverticular disease (31) Age (median): 66 (29-83) Gender (% male): 48 BMI: 25 Comorbidity status (%): ASA, I (67), ASA II (29), ASA III (2) | Sequence generation: NR Allocation concealment: unclear Blinding: NR Incomplete outcome data: 4% (n=2) not included in analyses Selective outcome reporting: BADL not reported Risk of bias: unclear
Gouvas 2012^25^ CCT Greece No funding indicated 2 X 2 study (open vs laparoscopic and fast track vs usual care) | Inclusion: diagnosed with adenocarcinoma of lower 2/3 of rectum Exclusion: emergency cases, tumor other than adenocarcinoma, distant metastases, neuromuscular disability, unsuitable for epidural anesthesia; ASA IV, refusal to consent to fast-track care or laparoscopy, different operation performed than originally scheduled | Intervention: laparoscopy combined with fast track (n=42) Control: laparoscopy usual care (n=33) Follow-up: 30 days Compliance: NR | N=75 Colorectal conditions (%): rectal cancer (100) Age (mean): 66 Gender (% male): 44 (fast track 52% vs 33% usual care, P=.001 across groups) BMI: 28 Comorbidity status (%): ASA I (52), ASA II (36), ASA III (12) | Sequence generation: NA, not randomized Allocation concealment: NA, grouped according to surgeon's preference Blinding: NR Incomplete outcome data: no Selective outcome reporting: no Risk of bias: high
Wang 2012^35^ China No funding indicated 2 X 2 study (open vs laparoscopic and fast track vs usual care) | Inclusion: no disease of immune system, no pre-operative radiotherapy or chemotherapy, no history of operation on abdominal and distant metastases; ASA score I–III, and self-care function prior to hospitalization Exclusion: association with other organ resection, conversion from laparoscopic operation to laparotomy, inability to place an epidural catheter, inability to infuse drugs, need for a stoma, and emergency operation | Intervention: laparoscopy combined with fast track (n=42) Control: laparoscopy usual care (n=42) Follow-up: 30 days Compliance: NR | N=84, data for 80 Colorectal conditions (%): colon cancer 100 Procedures (%): right hemicolectomy (39), left hemicolectomy (34), sigmoid colectomy (28) Age (median): 56 (both groups) Gender (% male): 66 BMI: 22 Comorbidity status (%): ASA I (39), ASA II (48), ASA3 (14) | Sequence generation: NR Allocation concealment: adequate Blinding: NR Incomplete outcome data: 5% (n=4) excluded from analyses Selective outcome reporting: no Risk of bias: unclear
Wang 2012^44^ China Social Development Fund | Inclusion: no previous abdominal surgery, no preoperative chemotherapy or radiotherapy, absence of distant metastases, ASA physical status I=III Exclusion: age < 18 years, cannot take care of themselves at home, undergone conversion to laparotomy, epidural catheter could not be inserted or did not work, anastomosis performed below 12cm from the anus, or patients receiving a stoma | Intervention: fast-track rehabilitation (n=54) Control: usual care (n=54) Follow-up: 30 days Compliance: study team made rounds 3 times daily to direct care but no compliance data reported | N=107 (data for 99) Colorectal condition (s): adenocarcinoma of colon Procedures (%):right hemicolectomy (34), left hemicolectomy (26), sigmoid colectomy (39) Age (median): 54 (fast track), 53 (usual care) Gender (% male): 60 BMI: median 22 (both groups) Comorbidity status (%): ASA I (28), ASA II (52), ASA III (20) | Sequence generation: unclear Allocation concealment: unclear Blinding: no; groups separated into different wards; outcomes observed by all members of study team and consensus reached Incomplete outcome data: 7% (n=8, unavailable PCA pump, conversion to laparotomy, stoma, metaptosis to pelvic floor); not included in analyses Selective outcome reporting: no Risk of bias: unclear
Wang 2012^46^ China No funding indicated | Inclusion: age > 65 years, diagnoses of colorectal cancer, undergoing laparoscopic colorectal resection Exclusion: distant metastasis involving pelvic invasion, the urethra, or iliac vessels; or were unable to undergo surgery because of poor cardiopulmonary function | Intervention: fast-track rehabilitation (n=40) Control: usual care (n=38) Follow-up: 3-44 months Compliance: NR | N=78 Colorectal conditions (%): colon cancer (68), rectal cancer (32) Procedures (%): right hemicolectomy (17), left hemicolectomy (4), sigmoid colectomy (29), anterior resection (25) Age (median): 71 (fast track), 72 (usual care) Gender (% male): 54 BMI: NR Comorbidity status (%): ASA I (28), ASA II (55), ASA III (17) | Sequence generation: adequate Allocation concealment: unclear Blinding: NR Incomplete outcome data: no Selective outcome reporting: no Risk of bias: medium
Vlug 2011^34^ LAFA-study The Netherlands (multisite) Industry 2 X 2 study (open vs laparoscopic and fast track vs usual care) | Inclusion: ages 40-80 years; ASA I, II, or III; elective segmental colectomy for histologically confirmed adenocarcinoma or adenoma; without evidence of metastatic disease Exclusion: prior midline laparotomy, unavailability of a laparoscopic surgeon, emergency surgery, or a planned stoma | Intervention: laparoscopy combined with fast track (n=106) Control: laparoscopy usual care (n=110) Follow-up: 30 days Compliance: 11.2 of the 15 components successfully applied per patient; 6.0 components of fast track were successfully applied per patient in the usual care group | N=216 (data for 209) Colorectal conditions (%): colon cancer and benign disease 100 Procedures (%): right colectomy (47), left colectomy (53) Age (mean): 67 Gender (% male): 58 BMI: 26 Comorbidity status (%) ASA I/II (81), III (19)Comorbidity (%): 69 | Sequence generation: NR Allocation concealment: adequate Blinding: patients and medical staff blinded for surgical approach until day of discharge) Incomplete outcome data: 3% (n=7) excluded from analyses (3 protocol violation, 2 withdrew consent) Selective outcome reporting: no Risk of bias: medium
Mixed Open and Laparoscopic Surgery Studies
Forsmo 2016^50^ Norway Funding: Internal (University Hospital) | Inclusion: age >18 years, scheduled for elective open or laparoscopic colorectal surgery for malignant or benign disease; also included rectal cancer patients who had pelvic radiation Exclusion: multivisceral resection planned, ASA IV, pregnancy, emergency operation, impaired mental capacity making consent difficult, inability to adapt to ERAS criteria NOTE: operating surgeon decided which surgical approach should be used | Intervention: enhanced recovery after surgery (n=162) Control: standard care (n=162) Follow-up: 30 days Compliance: significant differences between groups for a) preoperative counseling (ERAS 100%), b) carbohydrate drink (night before and 2 hr before surgery (ERAS 100%), c) laxative (ERAS 100%), d) intravenous anesthesia (ERAS 99%), e) earlier and increased oral intake and decreased intravenous fluid (ERAS group), f) earlier and increased mobilization (ERAS group), g) laxative POD1 (ERAS 80%, standard 3%), h) post-op oral opiates (ERAS 40%, standard 54%), i) post-op nasogastric tube (ERAS 3%, standard 12%), j) urine catheter removal (medians: ERAS POD2, standard POD4), k) thoracic epidural removal (medians: ERAS POD2, standard POD4) | N=324 (data for 307) Colorectal conditions (%): colon (46), rectal (54) (overall 79% malignant) Procedures (%): right (25), left or sigmoid (21), low anterior resection (30), abdominoperineal (20), proctocolectomy (5) Age (median): 65 (ERAS), 66 (usual care) Gender (% male): 54 BMI: NR Comorbidity status (%): ASA I (21), ASA II (63), ASA III (15) | Sequence generation: adequate Allocation concealment: adequate Blinding: none Incomplete outcome data: 5% excluded after randomization (protocol violation, emergency procedure, different hospital) Selective outcome reporting: no Risk of bias: low

ASA=American Society of Anesthesiologists score; BMI= body mass index; ERAS=enhanced recovery after surgery; NR=not reported; POSSUM=Physiological and Operative Severity Score for the enUmeration of Mortality and morbidity; POD=post-operative day; TME=total mesorectal excision

Table 2 Final Health Outcomes, Part A

Author Year Population | Length of stay, days mean (SD) | | Length of stay (total^a^), mean) (SD) | | Overall morbidity % (n/N) | | Overall mortality (note timepoint) % (n/N)
Author Year Population | ERAS | Control | ERAS | Control | ERAS | Control | ERAS | Control
Open Surgery Studies
Feng 2016^23^ Colorectal cancer | Post-operative 7.5 (2.2) (n=116) P=..001^b^ | Post-operative 8.6 (2.8) (n=114) | NR | NR | Surgical complications 6 (7/116) P=.03 | Surgical complications 15 (17/114) | NR | NR
Pappalardo 2016^31^ Rectal cancer | Dischargeable^c^ POD4 68% (17/25) POD5 20% (5/25) POD6 12% (3/25) P<.05 (overall) | Dischargeable^c^ POD4 16% (4/25) POD5 20% (5/25) POD6 32% (8/25) POD7 or longer 28% (7/25) | NR | NR | NR | NR | 0 (0/25) | 0 (0/25)
Jia 2014^27^ Colorectal cancer (elderly) | 9.0 (1.8) (n=117) P<.001 | 13.2 (1.3) (n=116) | NR | NR | NR | NR | Perioperative 0 (0/117) | Perioperative 0 (0/116)
Nanavati 2014^30^ Gastrointestinal surgery (3% cancer) | 4.7 (1.3) (n=30) P=.000 | 7.3 (1.4) (n=30) | NR | NR | NR | NR | 30 day 0 (0/30) | 30 day 0 (0/30)
Gouvas 2012^25^ CCT Rectal cancer | Median 7 (range 4-13) P=.001 | Median 8 (range 7-23) | Median 7 (range 4-25) P=.104 | Median 8 (range 7-25) | Overall morbidity (related to complications) 39 (14/36) P=.18^b^ | Overall morbidity (related to complications) 56 (25/45) | 30 day 3 (1/36) P=NS | 30 day 0 (0/45)
Ren 2011^32^ Colorectal cancer | 5.7 (1.6) (n=299) P<.001 | 6.6 (2.4) (n=298) | NR | NR | Post-op complications 9.7 (29/299) P=.90 | Post-op complications 9.4 (28/298) | 30 day 0 (0/299) | 30 day 0 (0/298)
Wang 2012^35^ Colon cancer | NR | NR | Post-operative 6.5 (4.1) (n=41) P<.05 | Post-operative 7.4 (4.2) (n=42) | Overall complications 17 (7/41) P=NS | Overall complications 24 (10/42) | 30 day 0 (0/41) P=NS | 30 day 2 (1/42)
Yang 2012^37^ Colorectal cancer | 6.0 (1.0) (n=32) P<.05 | 11.7 (3.8) (n=30) | NR | NR | Total infectious complications 6 (2/32) Total non-infectious complications 13 (4/32) Overall P=.09^b^ | Total infectious complications 27 (8/30) Total non-infectious complications 13 (4/30) | NR | NR
Vlug 2011^34^ Colon cancer and benign disease | Postoperative Median 6 (IQR 4.5-10) P=.032 | Postoperative Median 7 (IQR 6-10.5) | Postoperative Median 7 (IQR 5-11) P=NS | Postoperative Median 7 (IQR 6-13) | Overall morbidity (related to complications) 46 (43/93) P=NS | Overall morbidity (related to complications) 41 (41/98) | 30 day 4 (4/93) P=NS | 30 day 2 (2/98)
Wang 2011^36^ Colorectal cancer | Postoperative 5.1 (3.1) (n=106) P=.001 | Postoperative 7.6 (4.8) (n=104) | NR | NR | Patients with complications 19 (20/106) P=.02 | Patients with complications 38 (39/104) | 2 (2/106) P=.57 | 1 (1/104)
Ionescu 2009^26^ Rectosigmoid (58%) or colon (42%) cancer | 6.4 (3.4) (n=48) P=.001 | 9.2 (2.7) (n=48) | NR | NR | NR | NR | NR | NR
Muller 2009^29^ Colon surgery (87% malignant) with primary anastomosis | Median LOS 5 (2-30) (n=76) P<.0001 | Median LOS 9 (6-30) (n=75) | NR | NR | Total complications 21 (16/76) P=.001 | Total complications 49 (37/75) | NR | NR
Šerclová 2009^33^ Intestinal resection (78% Crohn's disease, 7% cancer) | 7.4 (1.3) (n=51) P<.001 | 10.4 (3.1) (n=52) | NR | NR | Total complications 22 (11/51) P=.003 | Total complications 48 (25/52) | 0 (0/51) | 0 (0/52)
Khoo 2007^28^ Colon (67%) or rectal (33%) cancer | Median 5 (range 3-37) P<.001 Rectal cancer 5.5 (4-37) Colon cancer 4 (3-13) | Median 7 (range 4-63) Rectal cancer 8.5 (4-63) olon cancer 7 (5-35) | Median 5 (range 3-37) P<.001 | Median 7 (range 4-63) | NR | NR | At day 14 0 (0/35) | At day 14 6 (2/35)
Gatt 2005^24^ Colon surgery (69% malignant) | Median 5 (IQR 4-9) P=.03 | Median 7.5 (IQR 6-10) | NR | NR | Total complications of surgery 47 (9/19) P=.08 | Total complications of surgery 75 (15/20) | At day 30 5 (1/19) P=.49^b^ | At day 30 0 (0/20)
Anderson 2003^22^ Colon surgery (72% malignant) | 4.0 (1.8) (n=14) Median 3 (IQR 2-7) P=.002 for both | 7.0 (2.1) (n=11) Median 7 (IQR 4-10) | NR | NR | NR | NR | At day 30 0 (0/14) P=NS | At day 30 9 (1/11)
Laparoscopic Studies
Ota 2017^42^ CCT Colorectal cancer NOTE: 97% (ERAS) and 91% (control) had laparoscopic surgery | Postoperative Median 8.5 (5-41) P<.001 Met discharge criteria POD3 (1-39) P<.001 | Postoperative Median 14 (7-46) Met discharge criteria POD10 (7-56) P<.001 | NR | NR | NR | NR | 0 (0/159) | 0 (0/161)
Scioscia 2017^43^ Bowel endometriosis | Median 3 (3-12) P<.001 | Median 7 (4-33) | NR | NR | NR | NR | NR | NR
Mari 2016^40^ Colorectal cancer (75%) or diverticular disease (25%) | Day of discharge 5.0 (2.6) P<.05 | Day of discharge 7.2 (3.0) | NR | NR | Patients with complications 17 (12/70) P=NS | Patients with complications 21 (15/70) | 0 (0/70) | 0 (0/70)
Wang 2015^45^ CCT Colon cancer | Postoperative 6.1 (1.7) P<.001 | Postoperative 8.7 (2.8) | NR | NR | Total morbidity 17.5% (10/57) P=.24 | Total morbidity 26.7% (16/60) | 0 (0/57) | 0 (0/60)
Feng 2014^38^ Rectal cancer | Postoperative 5.1 (1.4) (n=57) P<.001 | Postoperative 7.0 (2.3) (n=59) | All patients admitted 2-3 days before operation | | Total complications 3 (2/59) P=.03 | Total complications 17 (10/57) | 0 (0/57) | 0 (0/59)
Mari 2014^41^ Colon cancer (69%) or diverticular disease (31%) | Day of discharge 4.7 (2.4) (n=25) P<.005 | Day of discharge 7.7 (2.4) (n=25) | NR | NR | No major complications in either group | | 0 (0/25) | 0 (0/25)
Gouvas 2012^25^ CCT Rectal cancer | Median 4 (range 3-12) P<.001 | Median 8 (range 3-18) | Median 4 (range 3-31) P<.001 | Median 9 (range 3-22) | Overall morbidity (related to complications) 21 (9/42) P=.008 ^b^ | Overall morbidity (related to complications) 52 (17/33) | At day 30 2 (1/42) P=NS | At day 30 0 (0/33)
Wang 2012^35^ Colon cancer | NR | NR | Postoperative 5.2 (3.9) (n=40) P<.05 | Postoperative 6.3 (4.7) (n=40) | Complications, overall 8 (3/40) P=.48^b^ | Complications, overall 15 (6/40) | At day 30 3 (1/40) P=NS | At day 30 0 (0/40)
Wang 2012^44^ Adenocarcinoma of the colon | NR | NR | Postoperative, median 4 (2-12) P<.01 | Postoperative, median 5 (3-48) | Patients with 1 or more complications 12 (6/49) P=.30 | Patients with 1 or more complications 20 (10/50) | 2 (1/49) on POD3 P=.31 | 0 (0/50)
Wang 2012^46^ Colorectal cancer (elderly) | 5.5 (5-6) P<.001 (n=40) | 7.0 (6-8) (n=38) | NR | NR | Overall complications 5 (2/40) P=.045 | Overall complications 21 (8/38) | 1 death from hepatic metastasis after right hemicolectomy; 2 deaths from myocardial infarction Groups not reported; no significant difference between groups
Vlug 2011^34^ Colon cancer and benign disease | Postoperative Median 5 (IQR 4-7) P=.020 | Postoperative Median 6 (IQR 4-8.5) | Postoperative Median 5 (IQR 4-8) P=.026* | Postoperative Median 6 (IQR 4.5-9.5) | Overall morbidity (related to complications) 34 (34/100) P=NS | Overall morbidity (related to complications) 34 (37/109) | At day 30 2 (2/100) P=NS | At day 30 2 (2/109)
Mixed Open and Laparoscopic Surgery Studies
Forsmo 2016^50^ Colorectal cancer and benign disease | Postoperative Median 5 (IQR 2-50) P<.001 | Postoperative Median 7 (IQR 2-48) | Postoperative Median 5 (IQR 2-50) P=.001 | Postoperative Median 8 (IQR 2-48) | Overall morbidity 42 (65/154) P=.69 Patients with 1 or more major complications 11 (17/154) P=.33 | Overall morbidity 44 (68/153) Patients with 1 or more major complications 8 (12/153) | < 30 days 2 (3/154) P=.08 | < 30 days 0 (0/153)

ASA= American Society of Anesthesiologists Index; IQR= interquartile range; NR=not reported; NS=not statistically significant; POD=Postoperative day

a Initial and readmission

b Calculated (t-test or Fisher's exact test)

c Defined as meeting discharge criteria: normal oral feeding, complete canalization, abdominal drain and vesical catheter removed, no fever, no need for intravenous therapy;

NOTE: one patient in traditional care group not accounted for by study authors

Table 3 Final Health Outcomes, Part B

Author Year Population | Readmission rate % (n/N) | | Ileus % (n/N) | | Pain score, Clinically meaningful change (note score and define) | | Quality of life, Clinically meaningful change (note score and define)
Author Year Population | ERAS | Control | ERAS | Control | ERAS | Control | ERAS | Control
Open Surgery Studies
Feng 2016^23^ Colorectal cancer | NR | NR | 1 (1/116) P=.62 | 2 (2/114) | NR | NR | NR | NR
Pappalardo 2016^31^ Rectal cancer | NR | NR | NR | NR | NR | NR | NR | NR
Jia 2014^27^ Colorectal cancer (elderly) | NR | NR | NR | NR | NR | NR | NR | NR
Nanavati 2014^30^ Gastrointestinal surgery (3% cancer) | 3 (1/30) for leak P=NS | 3 (1/30) for leak | 3 (1/30) P=NS | 10 (3/30) | NR | NR | NR | NR
Gouvas 2012^25^ CCT Rectal cancer | Not reported by group, rates ranged from 9.5 to 15% P=NS between all groups | | 8 (3/36) P=.045^a^ | 27 (12/45) | NR | NR | NR | NR
Ren 2011^32^ Colorectal cancer | NR | NR | NR | NR | NR | NR | NR | NR
Wang 2012^35^ Colon cancer | 7 (3/41) P=NS | 5 (2/42) | NR | NR | NR | NR | NR | NR
Yang 2012^37^ Colorectal cancer | 0 (0/32) | 0 (0/30) | NR | NR | NR | NR | NR | NR
Vlug 2011^34^ Colon cancer and benign disease | 8 (7/93) P=NS | 7 (7/98) | Mechanical ileus requiring reoperation n=2 Prolonged postoperative (5 days) ileus n=5 | Mechanical ileus requiring reoperation n=5 Prolonged postoperative (5 days) ileus n=5 | NR | NR | NR | NR
Wang 2011^36^ Colorectal cancer | 4 (4/106) P=NS | 9 (9/110) | NR | NR | NR | NR | NR | NR
Ionescu 2009^26^ Rectosigmoid (58%) or colon (42%) cancer | 0 (0/48) | 0 (0/48) | NR | NR | NR | NR | NR | NR
Muller 2009^29^ Colon surgery (87% malignant) with primary anastomosis | 4 (3/76) P=NS^a^ | 3 (2/75) | Postoperative Ileus 4 (3/76) P=.72^a^ | Postoperative Ileus 5 (4/75) | NR | NR | NR | NR
Šerclová 2009^33^ Intestinal resection (78% Crohn's disease, 7% cancer) | 0 (0/51) | 0 (0/52) | NR | NR | VAS pain score (0-10) Clinically important difference in pain defined as 1 (standard deviation 0.5 to 1.5) Clinically significant lower pain for FT group vs non-FT group for postoperative days 0-5 | | NR | NR
Khoo 2007^28^ Colon (67%) or rectal (33%) cancer | 9 (3/35) P=.61^a^ | 3 (1/35) | NR | NR | NR | NR | NR | NR
Gatt 2005^24^ Colon surgery (69% malignant) | 5 (1/19) P=.17 | 20 (4/20) | 16 (3/19) P=NS^a^ | 15 (3/20) | NR | NR | NR | NR
Anderson 2003^22^ Colon surgery (72% malignant) | 0 (0/19) | 0 (0/20) | 7 (1/14) P=NS | 9 (1/11) | NR | NR | NR | NR
Laparoscopic Studies
Ota 2017^42^ CCT Colorectal cancer NOTE: 97% (ERAS) and 91% (control) had laparoscopic surgery | 1 (2/159) P=.16 | 0 (0/161) | 6 (10/159) P=.79 | 6 (9/161) | NR | NR | NR | NR
Scioscia 2017^43^ Bowel endometriosis | 18 (11/62) P=.69 | 16 (26/162) | NR | NR | NR | NR | NR | NR
Mari 2016^40^ Colorectal cancer (75%) or diverticular disease (25%) | NR | NR | 3 (2/70) P=NS | 6 (4/70) | NR | NR | NR | NR
Wang 2015^45^ CCT Colon cancer | NR | NR | 5.2 (3/57) P=NS | 8.3 (5/60) | Pain Scale QLQ-C30^b,c^ Change from pre-op to POD3: 24.6 P=.82 POD28: 7.9 P=.05 | Pain Scale QLQ-C30^b,c^ Change from pre-op to POD3: 22.2 POD28: 11.1 | Global Quality of Life (QLQ-C30)^b,c^ Change from pre-op to POD3: -10.9 P=.000 POD28: 0.5 P=.11 | Global Quality of Life (QLQ-C30)^b,c^ Change^s^ from pre-op to POD3: -18.7 POD28: -1.8
Feng 2014^38^ Rectal cancer | 0 (0/57) P=NS | 1.7 (1/59) for rectovaginal fistula | 0 (0/57) P=NS | 1.7 (1/59) | NR | NR | NR | NR
Mari 2014^41^ Colon cancer (69%) or diverticular disease (31%) | 0 (0/25) | 0 (0/25) | NR | NR | NR | NR | NR | NR
Gouvas 2012^25^ CCT | Not reported by group, rates ranged from 9.5 to 15% | 7 (3/42) P=.17^a^ | 18 (6/33) | NR | NR | NR | NR
Rectal cancer | P=NS between all groups
Wang 2012^35^ Colon cancer | 3 (1/40) P=NS | 8 (3/40) | NR | NR | NR | NR | NR | NR
Wang 2012^44^ Adenocarcinoma of the colon | 4 (2/49) P=.66 | 6 (3/50) | NR | NR | NR | NR | NR | NR
Wang 2012^46^ Colorectal cancer (elderly) | NR | NR | NR | NR | NR | NR | NR | NR
Vlug 2011^34^ Colon cancer and benign disease | 6 (6/100) P=NS^a^ | 6 (7/109) | Mechanical ileus requiring reoperation n=3 Prolonged postoperative ileus n=7 | Mechanical ileus requiring reoperation n=0 Prolonged postoperative ileus n=8 | NR | NR | NR | NR
Mixed Open and Laparoscopic Surgery Studies
Forsmo 2016^50^ Colorectal cancer and benign disease | 19 (29/154) P=.23 | 13 (21/153) | Mechanical, requiring reoperation 0 (0/154) P=.32 Prolonged postoperative 3 (4/154) P=.35 | Mechanical, requiring reoperation 1 (1/153) Prolonged postoperative 5 (7/153) | NR | NR | NR | NR

NR=not reported; NS=not statistically significant; POD=post-operative day

a Calculated (Fisher's exact test)

b QLQ-C30=European Organization for Research and Treatment of Cancer Quality of Life tool (cancer-specific); QLQ-CR29=colonic cancer specific module; higher scores for function and quality of life indicate higher function and higher quality of life

c Change of 5-10 points (on 0-100 scale) denotes clinically significant change of “little better (or worse)”; change of 10-20 points denotes “moderate better (or worse)”; change of >20 points denotes “very much better (or worse)”

Table 4 Intermediate Outcomes

Author Year Population | Gastrointestinal function (define), days Mean (SD) | | IV fluid administration | | Mobilization, days Mean (SD) | | Pain scale score (define) % (n/N)
Author Year Population | ERAS | Control | ERAS | Control | ERAS | Control | ERAS | Control
Open Surgery Studies
Feng 2016^23^ Colorectal cancer | Flatus 3.7 (1.1) P=.049 Stool passage 4.8 (1.6) P=.04 Oral intake 3.3 (1.3) P=.03 | Flatus 4.3 (1.5) Stool passage 5.8 (2.1) Oral intake 5.3 (1.6) | NR | NR | First ambulation 3.7 (1.7) P=.02 | First ambulation 5.4 (2.1) | NR | NR
Pappalardo 2016^31^ Rectal cancer | Bowel movement 52 hours P<.05 | Bowel movement 19 to 33 hours later than ERAS group | NR | NR | Mobilization POD1 100 (25/25) Ambulate POD2 100 (25/25) | Mobilization POD2 68% (17/25) POD3 32% (8/25) Ambulate subsequent day for 100% | NR | NR
Jia 2014^27^ Colorectal cancer (elderly) | Flatus, hours 48.5 (9.6) (n=117) P<.001 | Flatus, hours 77.7 (7.2) (n=116) | NR | NR | NR | NR | NR | NR
Nanavati 2014^30^ Gastrointestinal surgery (3% cancer) | Flatus 2.8 (n=30) Stool passage 4.0 P<.05 for both | Flatus 4.0 (n=30) Stool passage 6.2 | NR | NR | NR | NR | NR | NR
Gouvas 2012^25^ CCT Rectal cancer | First bowel movement Median 4 (range 1-7) P<.001 | First bowel movement Median 6 (range 1-12) | NR | NR | NR | NR | NR | NR
Ren 2011^32^ Colorectal cancer | Flatus, hours 53.7 (17.1) (n=299) Bowel movement, hours 73.7 (23.7) P<.001 for both | Flatus, hours 63.1 (20.0) (n=298) Bowel movement, hours 88.8 (29.5) | NR | NR | NR | NR | NR | NR
Wang 2012^35^ Colon cancer | NR | NR | NR | NR | NR | NR | NR | NR
Yang 2012^37^ Colorectal cancer | Flatus 2 (1) (n=32) Defecation 3.8 (1.6) Soft Diet 4.0 (2.0) P<.05 for all | Flatus 4 (2) (n=30) Defecation 6.4 (2.5) Soft Diet 8.2 (2.2) | NR | NR | NR | NR | NR | NR
Vlug 2011^34^ Colon cancer and benign disease | Medians Tolerate solid food 1 (IQR 1–3) Flatus 1 (IQR 1–3) Stool passage 3 (IQR 2–4) Overall discharge criteria (including components above and mobilization) achieved significantly earlier in ERAS group versus usual care | Medians Tolerate solid food 3 (IQR 2–5) Flatus 2 (IQR 1–3) Stool passage 4 (IQR 3–6) | NR | NR | Mobilization, median minutes POD1 120 (60-215) Mobilization as pre-operative, median days 4 (IQR 3–7) | Mobilization, median minutes POD1 20 (0-60) Mobilization as pre-operative, median days 6 (IQR 5–8) | SF-36 Bodily Pain score returned to baseline at 4 weeks with no significant differences across groups
Wang 2011^36^ Colorectal cancer | Flatus 2.1 (2.0)(n=106) P=.001 | Flatus 3.2 (2.5)(n=104) | NR | NR | Walk on surgery day 35% (11/106) P=.001 Walk on day 1 53% (56/106) P=.000 Walk on day 2 85% (90/106) P=.001 | Walk on surgery day 0% (0/104) Walk on day 1 23% (24/104) Walk on day 2 59% (61/104) | NR | NR
Ionescu 2009^26^ Rectosigmoid (58%) or colon (42%) cancer | Bowel function, hours 43.7 (14.9) (n=48) P=.042 Solid Food intake, hours 42.2 (12.7) P=.01 Fluid intake, hours 10.9 (8.1) P=.001 | Bowel function, hours 52.02 (23.7) (n=48) Solid Food intake, hours 64.3 (23.3) Fluid intake, hours 23.5 (16.9) | NR | NR | Complete Mobilization, hours 19.6 (8.6) P=.001 | Complete Mobilization, hours 37.1 (23.9) | NR | NR
Muller 2009^29^ Colon surgery (87% malignant) with primary anastomosis | NR | NR | NR | NR | NR | NR | NR | NR
Šerclová 2009^33^ Intestinal resection (78% Crohn's disease, 7% cancer) | Bowel Movement 1.3 (0.8) (n=51) Stool 2.1 (1.1) P<.001 for both Semi-solid and solid diet on Day 5 100 (51/51) P<.001 | Bowel Movement 3.1 (1.0) (n=52) Stool 3.9 (1.1) Semi-solid and solid diet on Day 5 20 (10/52) | NR | NR | Day 0 64% could walk Day 1 54% walked 44% used treadmill 2% rehabilitated in sitting position only | Day 0 0% could walk Day 1 14% walked 2% used treadmill 68% rehabilitated in sitting position only 16% rehabilitated in bed | Mean daily VAS values (post-op day 0 to 5) 1.6, 1.0, 0.6, 0.3, 0, 0 | Mean daily VAS values (post-op day 0 to 5) 3.2, 2.4, 1.8, 1.6, 1.2, 0.8
Khoo 2007^28^ Colon (67%) or rectal (33%) cancer | Tolerate solid diet Median 1 (range 0-6) Stool passage/stoma functioning 3 (range 1-5) P<.001 for both | Tolerate solid diet Median 4 (range 2-9) Stool passage/stoma functioning 5 (range 0-23) | Median over 47 hours peri-operatively 3000 mL | Median over 47 hours peri-operatively 6263 mL | Median 2 (range 1–10) P<.001 | Median 4 (range 2–32) | NR | NR
Gatt 2005^24^ Colon surgery (69% malignant) | Ability to tolerate diet of 3 light meals a day Median, hours approx. 50 P=.04 | Ability to tolerate diet of 3 light meals a day Median, hours approx. 90 | Duration of intravenous fluids from the time of surgery Median, hours approx. 35 P=.007 | Duration of intravenous fluids from the time of surgery Median, hours approx. 68 | No differences between the groups in time to be able to walk to toilet unaided (P=.79) | | No differences between the groups in pain scores
Anderson 2003^22^ Colon surgery (72% malignant) | Ability to tolerate diet of 3 light meals a day Median, hours 48 (IQR 33-55) P<.001 | Ability to tolerate diet of 3 light meals a day Median, hours 76 (IQR 70-110) | Discontinuation of supplemental intravenous fluids Median, hours 26 (IQR 24-37) P<.001 | Discontinuation of supplemental intravenous fluids Median, hours 57 (IQR 42-105) | Walk to toilet unaided Median, hours 46 (IQR 37-54) P=.04 | Walk to toilet unaided Median, hours 69 (IQR 44-121) | Post-op day 1 median pain scores at rest, on movement, and on coughing all significantly higher in usual care group versus intervention group Post-op day 7 pain on coughing remained significantly higher in usual care group
Laparoscopic Studies
Ota 2017^42^ CCT Colorectal cancer NOTE: 97% (ERAS) and 91% (control) had laparoscopic surgery | Flatus Median 1 (1-5) P<.001 Bowel movement 2 (1-6) P<.001 Oral food 1 (1-31) P<.001 | Flatus Median 2 (1-5) Bowel movement 3 (1-7) Oral food 3 (1-9) | IV fluid until POD Median 1 (1-11) P<.001 | IV fluid until POD Median 5 (3-35) | NR | NR | NR | NR
Scioscia 2017^43^ Bowel endometriosis | NR | NR | NR | NR | NR | NR | NR | NR
Mari 2016^40^ Colorectal cancer (75%) or diverticular disease (25%) | Flatus 1.6 (0.7) P<.05 Bowel movement P=NS (data NR) Solid diet 1.5 (0.9) P<.05 | Flatus 2.1 (0.8) Bowel movement (data NR) Solid diet 3.0 (0.5) | NR | NR | Walk ≥100 m 1.5 (0.7) P<.05 | Walk ≥100 m 2.6 (0.9) | NR | NR
Wang 2015^45^ CCT Colon cancer | Flatus, hours 60.9 (11.1) P=.000 Bowel movement, hours 75.1 (14.9) P=.002 | Flatus, hours 74.2 (16.3) Bowel movement, hours 85.5 (19.4) | NR | NR | First time out of bed, hours 15.3 (3.6) P=.000 | First time out of bed, hours 42.5 (14.7) | NR | NR
Feng 2014^38^ Rectal cancer | Flatus, hours 53.4 (23.6) P=.001 First defecation, hours 65.2 (22.2) P=.000 All (n=57) | Flatus, hours 67.9 (20.1) First defecation, hours 87.0 (24.9) All (n=59) | NR | NR | NR | NR | Pain (VAS) POD1 4.3 (1.0) P=.02 POD3 2.7 (1.2) P=.03 POD5 2.3 (1.5) P=.11 | Pain (VAS) POD1 3.4 (1.0) POD3 1.8 (0.9) POD5 1.6 (1.2)
Mari 2014^41^ Colon cancer (69%) or diverticular disease (31%) | First bowel movement 0.3 (0.65) (n=25) Stool passage 1.6 (1.0) Flatus 0.9 (0.8) Solid diet 1.2 (0.4) All P<.005 | First bowel movement 1.7 (0.5) (n=25) Stool passage 5 (1.8) Flatus 2.1 (0.9) Solid diet 3.8 (1.0) | NR | NR | Walk at least 60-meters 1.3 (0.8) (n=25) P<.005 | Walk at least 60-meters 3.6 (0.5) (n=25) | Pain, based on VAS pain scale Higher pain perception in immediate postoperative time in ERAS group (P<.05) but non-significant after 5 hours; From day 1, ERAS patients referred less pain as compared with control patients. P=NS
Gouvas 2012^25^ CCT Rectal cancer | First bowel movement Median 2 (range 0-6) P<.001 | First bowel movement Median 5 (range 2-12) | NR | NR | NR | NR | NR | NR
Wang 2012^35^ Colon cancer | NR | NR | NR | NR | NR | NR | NR | NR
Wang 2012^44^ Adenocarcinoma of the colon | Flatus, median 2 (1-6) P=.017Semi-liquid diet 1 (1-3) P<.001 Normal diet 3 (2-5) P<.001 All (n=49) | Flatus, median 3 (1-7) Semi-liquid diet 2 (1-5) Normal diet 4 (3-7) All (n=50) | NR | NR | Autonomic mobilization 1 (1-3) P<.001 | Autonomic mobilization 2 (1-3) | NR | NR
Wang 2012^46^ Colorectal cancer (elderly) | Flatus, median hours 31 (26-40) P=.001 Bowel movement, median hours 55 (48-63) P=.009 Fluid diet, median hours 12 (11-16) P<.001 All (n=40) | Flatus, median hours 38 (32-51) Bowel movement, median hours 64 (51-71) Fluid diet, median hours 47 (35-50) All (n=38) | NR | NR | Ambulation, median hours 12 (10-14) P<.001 (n=40) | Ambulation, median hours 19 (16-24) (n=38) | NR | NR
Vlug 2011^34^ Colon cancer and benign disease | Medians Tolerate solid food 1 (IQR 1-2) Flatus 1 (IQR 1-2) Stool passage 2 (IQR 1-4) Overall discharge criteria (including components above and mobilization) achieved significantly earlier in ERAS group versus usual care | Medians Tolerate solid food 2 (IQR 1-3) Flatus 2 (IQR 1–3) Stool passage 3 (IQR 2-4) | NR | NR | Mobilization, median minutes POD1 120 (50-240) Mobilization as pre-operative, median days 3 (IQR 2-5) | Mobilization, median minutes POD1 30 (15-60) Mobilization as pre-operative, Median days 5 (IQR 4-7) | NR | NR
Mixed Open and Laparoscopic Surgery Studies
Forsmo 2016^50^ Colorectal cancer and benign disease | Flatus, median 1 (0-4) Bowel movement, median 1 (1-6) Both P<.001 Tolerate solid food, median 2 (0-9) P=.61 | Flatus, median 1 (1-14) Bowel movement, median 2 (1-14) Both P<.001 Tolerate solid food, median 1 (0-12) | IV fluid, first 24 hrs (including intraoperative), L (median) 3.9 (1.9-9.0) P=.001 First 7 days 5.6 (1.9-19.2) P<.001 | IV fluid, first 24 hrs (including intraoperative), L (median) 4.4 (1.8-9.5) First 7 days 7.8 (2.8-30.1) | NR | NR | NR | NR

IQR=interquartile range; NR=not reported; NS=not statistically significant; POD=post-operative day; VAS= Visual Analogue Scale

Table 5 Harms Associated with Enhanced Recovery, Part A

Author Year Population | Surgical complications (define) % (n/N) | | Need for reoperation % (n/N) | | Bleeding % (n/N) | | General or gastrointestinal complications % (n/N)
Author Year Population | ERAS | Control | ERAS | Control | ERAS | Control | ERAS | Control
Open Surgery Studies
Feng 2016^23^ Colorectal cancer | Anastomotic leakage 1 (1/116) P=.37 Wound infection 1 (1/116) P=.37 | Anastomotic leakage 3 (3/114) Wound infection 3 (3/114) | NR | NR | Anastomotic bleeding 1 (1/116) P=.62 | Anastomotic bleeding 2 (2/114) | NR | NR
Pappalardo 2016^31^ Rectal cancer | Anastomotic leakage 12 (3/25) (1 major) P=NS | Anastomotic leakage 8 (2/25) (1 major) | NR | NR | NR | NR | NR | NR
Jia 2014^27^ Colorectal cancer (elderly) | Infection of incision 5 (6/117) P=.57 Anastomotic leakage 3 (3/117) P=1.0 | Infection of incision 7 (8/116) Anastomotic leakage 2 (2/116) | NR | NR | NR | NR | Intestinal obstruction 3 (4/117) P=.74 | Intestinal obstruction 5 (6/116)
Nanavati 2014^30^ Gastrointestinal surgery (3% cancer) | Anastomotic leakage 0 (0/30) P=NS Wound infection 3 (1/30) Wound dehiscence 3 (1/30) Total 13 (4/30) P=NS | Anastomotic leakage 3 (1/30) Wound infection 0 (0/30) Wound dehiscence 0 (0/30) Total 17 (5/30) | 0 (0/130) | 3 (1/30) for anastomotic leak | NR | NR | NR | NR
Gouvas 2012^25^ CCT Rectal cancer | Leak 11 (4/36) Wound complications 31 (11/36) P=NS for both | Leak 7 (3/45) Wound complications 38 (17/45) | Not reported by group, rates ranged from 4 to 15% P=NS between all groups | | 8 (3/36) P=.21^a^ | 20 (9/45) | Obstruction 3 (1/36) P=NS | Obstruction 2 (1/45)
Ren 2011^32^ Colorectal cancer | Wound infection 2 (5/299) Anastomotic Leaks 2 (5/299) Intestinal Perforation 0 (1/299) P=NS for all | Wound infection 2 (5/298) Anastomotic Leaks 2 (5/298) Pancreatic Leakage 0 (1/298) | NR | NR | NR | NR | Intestinal obstruction 2 (6/299) P=NS Gastric retention 3 (10/299) P=.30^a^ Diarrhea 0 (1/299) | Intestinal Obstruction 2 (7/298) Gastric retention 2 (5/298)
Wang 2012^35^ Colon cancer | “Surgical”^b^ 7 (3/41) P=NS | “Surgical”^b^ 7 (3/42) | NR | NR | NR | NR | “General”^b^ 10 (4/41) P=NS | “General”^b^ 17 (7/42)
Yang 2012^37^ Colorectal cancer | Surgical site infection 3 (1/32) P=.61 Anastomotic leaks 0 (0/32) | Surgical site infection 7 (2/30) Anastomotic leaks 0 (0/30) | NR | NR | NR | NR | Dysbiosis 3 (1/32) P=.10^a^ | Dysbiosis 17 (5/30)
Vlug 2011^34^ Colon cancer and benign disease | Major complications (including non-surgical) 20 (18/93) P=NS Including: Anastomotic leakage n=8 (2 fatal) Iatrogenic bowel perforation n=2 Dehiscence n=6 Wound infection 16 total | Major complications (including non-surgical) 21 (21/98) Including: Anastomotic leakage n=7 Iatrogenic bowel perforation n=1 Dehiscence n=3 Wound infection 10 total | 14 (13/93) P=NS | 18 (18/98) | NR | NR | Minor complications (including surgical) 26 (25/93) P=NS | Minor complications (including surgical) 19 (20/98)
Wang 2011^36^ Colorectal cancer | Anastomotic leakage 4 (4/106) Wound infection 4 (4/106) P=NS for both | Anastomotic leakage 2 (2/104) Wound infection 7 (7/104) | 2 (2/106) for bowel obstruction | 5 (5/104) for bowel obstruction | NR | NR | Bowel obstruction 2 (2/106) P=.28 Re-insertion of nasogastric tube 4 (4/106) P<.05 | Bowel obstruction 5 (5/104) Re-insertion of nasogastric tube 11 (12/104)
Ionescu 2009^26^ Rectosigmoid (58%) or colon (42%) cancer | Anastomotic leak 2 (1/48) Wound infection 8 (4/48) P=NS for both | Anastomotic leak 2 (1/48) Wound infection 10 (5/48) | 0 (0/48) for anastomotic leak P=NS^a^ | 2 (1/48) for anastomotic leak | NR | NR | Post-operative nausea and vomiting 35 (17/48) P=.54 | Post-operative nausea and vomiting 43 (21/48)
Muller 2009^29^ Colon surgery (87% malignant) with primary anastomosis | Wound infection 5 (4/76) P=.37^a^ Anastomotic leaks 1 (1/76) P=.62^a^ | Wound infection 9 (7/75) Anastomotic leaks 3 (2/75) | NR | NR | Postoperative bleeding 1 (1/76) P=.62^a^ | Postoperative bleeding 3 (2/75) | “Other events” 0 (0/76) P=.12^a^ | “Other events” 4 (3/75)
Šerclová 2009^33^ Intestinal resection (78% Crohn's disease, 7% cancer) | >1 complication 0 (0/51) P=.50^a^ Wound complications 8 (4/51) P=.003 | >1 complication 4 (2/52) Wound complications 33 (17/52) | NR | NR | NR | NR | Vomiting Day of surgery 8% POD1 16% POD2 2%* POD3 2% POD4 2% *P<.05 (P=NS all other days) | Vomiting Day of surgery 14% POD1 12% POD2 16% POD3 10% POD4 8%
Khoo 2007^28^ Colon (67%) or rectal (33%) cancer | Anastomotic leakage 3 (1/35) P=.61^a^ | Anastomotic leakage 9 (3/35) | NR | NR | NR | NR | Nasogastric tube reinsertion 9 (3/35) P=NS^a^ | Nasogastric tube reinsertion 11 (4/35)
Gatt 2005^24^ Colon surgery (69% malignant) | Wound infection 0 (0/19) P=.11^a^ | Wound infection 20 (4/20) | NR | NR | NR | NR | Diarrhea/nausea 5 (1/19) P=NS^a^ | Diarrhea/nausea 10 (2/20)
Anderson 2003^22^ Colon surgery (72% malignant) | Wound infection 7 (1/14) P=NS^a^ | Wound infection 0 (0/11) | NR | NR | NR | NR | NR | NR
Laparoscopic Studies
Ota 2017^42^ CCT Colorectal cancer NOTE: 97% (ERAS) and 91% (control) had laparoscopic surgery | Surgical complications (total) 17 (27/159) P=NS Surgical site infection 3 (5/159) P=1.0 Intraperitoneal infection 0 (0/159) P=.25 Anastomotic leakage 3 (4/159) P=.99 | Surgical complications (total) 16 (26/161) Surgical site infection 4 (6/161) Intraperitoneal infection 2 (3/161) Anastomotic leakage 3 (4/161) | 1 (2/159) P=.16 | 4 (6/161) | Anastomotic bleeding 5 (8/159) P=.02 Intraperitoneal bleeding 0 (0/159) P=.08 | Anastomotic bleeding 1 (1/161) Intraperitoneal bleeding 2 (3/161) | NR | NR
Scioscia 2017^43^ Bowel endometriosis | NR | NR | For severe complications 6.5 (4/62) P=.20 | For severe complications 8.5 (14/162) | Need for transfusion 3.2 (2/62) P=.73 | Need for transfusion 5.5 (9/162) | NR | NR
Mari 2016^40^ Colorectal cancer (75%) or diverticular disease (25%) | Wound infection 3 (2/70) Anastomotic fistula 3 (2/70) P=NS for both | Wound infection 1 (1/70) Anastomotic fistula 4 (3/70) | NR | NR | Proctorrhagia 1 (1/70) P=NS | Proctorrhagia 4 (3/70) | Vomiting 7 (5/70) P=NS | Vomiting 3 (2/70)
Wang 2015^45^ CCT Colon cancer | Wound infection 3.5 (2/57) Anastomotic leakage 1.8 (1/57) P=NS^a^ for b oth | Wound infection 3.3 (2/60) Anastomotic leakage 3.3 (2/60) | NR | NR | NR | NR | Gastric retention 1.8 (1/57) P=NS^a^ | Gastric retention 3.3 (2/60)
Feng 2014^38^ Rectal cancer | Change to open surgery due to difficulty in tumor resection (4/57) Incision Infection 0 (0/57) Anastomotic leakage 0 (0/57) Abdominal infection 0 (0/57) All P=NS | Change to open surgery due to difficulty in tumor resection (3/59) Incision Infection 1.7 (1/59) Anastomotic leakage 6.8 (4/59) Abdominal infection 0 (0/59) | 0 (0/57) P=NS | 1.7 (1/59) for anastomotic leak | NR | NR | Rectovaginal fistula 0 (0/57) P=NS | Rectovaginal fistula 1.7 (1/59)
Mari 2014^41^ Colon cancer (69%) or diverticular disease (31%) | No anastomotic leaks | No anastomotic leaks | NR | NR | NR | NR | NR | NR
Gouvas 2012^25^ CCT Rectal cancer | Leak 10 (4/42) Wound complications 7 (3/42) P=NS for both | Leak 15 (5/33) Wound complications 12 (4/33) | Not reported by group, rates ranged from 4 to 15% P=NS between all groups | | 0 (0/42) | 0 (0/33) | Obstruction 0 (0/42) | Obstruction 3 (1/33)
Wang 2012^35^ Colon cancer | “Surgical”^b^ 3 (1/40) P=NS | “Surgical”^b^ 5 (2/40) | NR | NR | NR | NR | “General”^b^ 5 (2/40) P=NS | “General”^b^ 10 (4/40)
Wang 2012^44^ Adenocarcinoma of the colon | Anastomotic leakage 0 (0/49) Wound infection 6 (3/49) P=NS for both | Anastomotic leakage 2 (1/50) Wound infection 4 (2/50) | None | None | NR | NR | Obstruction 0 (0/49) | Obstruction 2 (1/50)
Wang 2012^46^ Colorectal cancer (elderly) | Incision infection 3 (1/40) P=.35 (n=40) Leakage 0 (0/40) | Incision infection 8 (3/38) (n=38) Leakage 0 (0/38) | NR | NR | NR | NR | Obstruction 0 (0/40) | Obstruction 5 (2/38)
Vlug 2011^34^ Colon cancer and benign disease | Anastomotic leakage n=7 Wound infection 6 total | Anastomotic leakage n=6 (1 fatal) Iatrogenic bowel perforation n=2 (1 patient died) Dehiscence n=3 Wound infection 8 total | 10 (10/100) P=NS | 10 (11/109) | NR | NR | NR | NR
Mixed Open and Laparoscopic Surgery Studies
Forsmo 2016^50^ Colorectal cancer and benign disease | Anastomotic leakage^c^ Colon: 5 (3/59) P=.45 Rectum: 12 (7/58) P=.17 Wound infection Abdominal: 7 (10/154) P=.51 Perineal: 25 (8/154) P=.81 Abdominal wall dehiscence 3 (5/154) P=.99 | Anastomotic leakage^c^ Colon: 3 (2/77) Rectum: 4 (2/45) Wound infection Abdominal: 9 (13/153) Perineal: 32 (9/153) Abdominal wall dehiscence 3 (5/153) | 11 (17/154) P=.24 | 7 (11/153) | NR | NR | NR | NR

NR=not reported; NS=not statistically significant

a Calculated (Fisher's exact test)

b Surgical complications includes wound complications, anastomotic leak, and bowel obstruction requiring re-operation; General complications includes cardiovascular, pulmonary, thromboembolic, urinary and other complications

c In patients with an anastomosis

Table 6 Harms Associated with Enhanced Recovery, Part B

Author Year | Foley catheter re-insertion/other renal or urologic complications % (n/N) | | Aspiration pneumonia or pulmonary infection % (n/N) | | Vascular or cardiovascular complications % (n/N) | | Miscellaneous complications % (n/N)
Author Year | ERAS | Control | ERAS | Control | ERAS | Control | ERAS | Control
Open Surgery Studies
Feng 2016^23^ Colorectal cancer | Urinary retention 2 (2/116) P=.68 | Urinary retention 3 (3/114) | Pulmonary infection 1 (1/116) P=.21 | Pulmonary infection 4 (4/114) | NR | NR | NR | NR
Pappalardo 2016^31^ Rectal cancer | Urinary complications 0 (0/25) | Urinary complications 0 (0/25) | NR | NR | Vascular complications 0 (0/25) | Vascular complications 0 (0/25) | Pulmonary complications (not specified) 0 (0/25) | Pulmonary complications 0 (0/25)
Jia 2014^27^ Colorectal cancer (elderly) | UTI 4 (5/117) P=.05 | UTI 11 (13/116) | Pulmonary infection 5 (6/117) P=.006 | Pulmonary infection 16 (19/116) | Heart failure 3 (4/117) P=.02 DVT 3 (4/117) P=.34 | Heart failure 11 (13/116) DVT 6 (7/116) | Post-op delirium^a^ 3 (4/117) P=.008 | Post-op delirium^a^ 13 (15/116)
Nanavati 2014^30^ Gastrointestinal surgery (3% cancer) | NR | NR | NR | NR | NR | NR | NR | NR
Gouvas 2012^25^ CCT Rectal cancer | Urinary retention 11 (4/36) P=NS | Urinary retention 20 (9/45) | Chest infection 17 (6/36) P=.004 ^b^ | Chest infection 49 (22/45) | DVT 3 (1/36) Pulmonary embolism 3 (1/36) | DVT 16 (7/45) Pulmonary embolism 4 (2/45) | NR | NR
Ren 2011^32^ Colorectal cancer | NR | NR | NR | NR | Cardiovascular and cerebro-vascular complication 0 (1/299) | Cardiovascular and cerebro-vascular complication 2 (5/298) | NR | NR
Wang 2012^35^ Colon cancer | NR | NR | NR | NR | NR | NR | NR | NR
Yang 2012^37^ Colorectal cancer | Urine distension 3 (1/32) P=NS | Urine distension 3 (1/30) | Pneumonia 0 (0/32) P=.48 | Pneumonia 3 (1/30) | Arrhythmia 0 (0/32) P=NS | Arrhythmia 3 (1/30) | Stress ulcer 0 (0/32) P=NS | Stress ulcer 3 (1/30)
Vlug 2011^34^ Colon cancer and benign disease | Urine retention n=6 complications | Urine retention n=1 complication | NR | NR | None reported | CVA n=2 complications (1 fatal) | Other infectious complications n=11 Respiratory n=2 complications (1 fatal) | Other infectious complications n=14 Respiratory n=4 complications
Wang 2011^36^ Colorectal cancer | Catheter reinsertion 4 (4/106) P=.06^b^ Urinary retention 5 (5/106) P=.01^b^ Urinary tract complication 2 (2/106) P=NS | Catheter reinsertion 11 (12/104) Urinary retention 15 (16/104) Urinary tract complication 5 (5/104) | NR | NR | Cardiac complication 2 (2/106) Thrombo-embolic complication 1 (1/106) P=NS^b^ for both | Cardiac complication 5 (5/104) Thrombo-embolic complication 3 (3/104) | Pulmonary complication (not specified) 3 (3/106) P=.13^b^ | Pulmonary complication 8 (8/104)
Ionescu 2009^26^ Rectosigmoid (58%) or colon (42%) cancer | UTI 0 (0/48) Hematuria 2 (1/48) P=NS for both | UTI 6 (3/48) Hematuria 0 (0/48) | NR | NR | Pulmonary embolism 0 (0/48) P=NS | Pulmonary embolism 2 (1/48) | Postoperative hernia 0 (0/48) P=NS | Postoperative hernia 2 (1/48)
Muller 2009^29^ Colon surgery (87% malignant) with primary anastomosis | Urinary infection/retention 4 (3/76) P=.49^b^ | Urinary infection/retention 7 (5/75) | Pneumonia or respiratory events 1 (1/76) | Pneumonia or respiratory events 5 (4/75) | Cardiovascular events 4 (3/76) P=.08^b^ | Cardiovascular events 12 (9/75) | NR | NR
Šerclová 2009^33^ Intestinal resection (78% Crohn's disease, 7% cancer) | NR | NR | NR | NR | NR | NR | NR | NR
Khoo 2007^28^ Colon (67%) or rectal (33%) cancer | Re-insertion due to urinary retention 11 (4/35) P=.11^b^ UTI 3 (1/35) P=NS | Re-insertion due to urinary retention 0 (0/35) UTI 6 (2/35) | NR | NR | Cardio-respiratory compromise 0 (0/35) P=.11^b^ | Cardio-respiratory compromise 11 (4/35) | Pressure sores 0 (0/35) | Pressure sores 9 (3/35)
Gatt 2005^24^ Colon surgery (69% malignant) | UTI 0 (0/19) P=.49^b^ | UTI 10 (2/20) | Chest infection 5 (1/19) P=NS | Chest infection 0 (0/20) | DVT 10 (2/19) P=.23^b^ | DVT 0 (0/20) | NR | NR
Anderson 2003^22^ Colon surgery (72% malignant) | UTI 7 (1/14) P=.56^b^ | UTI 18 (2/11) | NR | NR | Atrial fibrillation 0 (0/14) | Atrial fibrillation 9 (1/11) | Respiratory depression related to patient-controlled analgesia 0 (0/14) | Respiratory depression related to patient-controlled analgesia 9 (1/11)
Laparoscopic Studies
Ota 2017^42^ CCT Colorectal cancer NOTE: 97% (ERAS) and 91% (control) had laparoscopic surgery | Hepatorenal complication 0 (0/159) P=.32 UTI 0 (0/159) | Hepatorenal complication 1 (1/161) UTI 0 (0/161 | NR | NR | Cardiovascular complication 0 (0/159) P=.32 DVT 0 (0/159) | Cardiovascular complication 1 (1/161) DVT 0 (0/161) | Respiratory complication (not specified) 0 (0/159) P=.32 Delirium 0 (0/159) P=.25 | Respiratory complication 1 (1/161) Delirium 2 (3/161)
Scioscia 2017^43^ Bowel endometriosis | NR | NR | NR | NR | NR | NR | Pyrexia 14.5 (9/62) P=.83 | Pyrexia 12.7 (21/162)
Mari 2016^40^ Colorectal cancer (75%) or diverticular disease (25%) | Urinary retention 1 (1/70) P=NS | Urinary retention 4 (3/70) | Pneumonia 4 (3/70) P=NS | Pneumonia 7 (5/70) | Atrial fibrillation 0 (0/70) P=NS | Atrial fibrillation 1 (1/70)
Wang 2015^45^ CCT Colon cancer | NR | NR | Pulmonary infection 1.8 (1/57) P=.62^b^ | Pulmonary infection 5.0 (3/60) | Cardiovascular events 3.5 (2/57) P=NS^b^ | Cardiovascular events 3.3 (2/60) | NR | NR
Feng 2014^38^ Rectal cancer | Urinary retention 1.8 (1/57) Urinary infection 0 (0/57) P=NS for both | Urinary retention 3.4 (2/59) Urinary infection 0 (0/59) | Pneumonia 1.8 (1/57) P=NS | Pneumonia 1.7 (1/59) | DVT 0 (0/57) | DVT 0 (0/59) | NR | NR
Mari 2014^41^ Colon cancer (69%) or diverticular disease (31%) | NR | NR | NR | NR | NR | NR | Respiratory distress 4 (1/25) P=NS^b^ | Respiratory distress 0 (0/25)
Gouvas 2012^25^ CCT Rectal cancer | Urinary retention 5 (2/42) P=.01^b^ | Urinary retention 24 (8/33) | Chest infection 10 (4/42) P=.20^b^ | Chest infection 21 (7/33) | DVT 2 (1/42) P=NS | DVT 9 (3/33) | NR | NR
Wang 2012^35^ Colon cancer | NR | NR | NR | NR | NR | NR | NR | NR
Wang 2012^44^ Adenocarcinoma of the colon | Catheter reinsertion 8 (4/49) UTI 2 (1/49) P=NS for both | Catheter reinsertion 14 (7/50) UTI 2 (1/50) | NR | NR | Cardiac complication 0 (0/49) P=.49^b^ Thrombo-embolic complication 0 (0/49) P=NS^b^ | Cardiac complication 4 (2/50) Thrombo-embolic complication 2 (1/50) | Pulmonary complication (not specified) 2 (1/49) P=NS^b^ | Pulmonary complication 4 (2/50)
Wang 2012^46^ Colorectal cancer (elderly) | NR | NR | Intrapulmonary infection 3 (1/40) P=.35 | Intrapulmonary infection 8 (3/38) | NR | NR | NR | NR
Vlug 2011^34^ Colon cancer and benign disease | Urine retention n=4 complications | Urine retention n=6 complications | NR | NR | CVA n=1 complication (fatal) | CVA n=0 | Other infectious complications n=8 Respiratory n=2 complications (1 fatal) | Other infectious complications n=9 Respiratory n=2 complications
Mixed Open and Laparoscopic Surgery Studies
Forsmo 2016^50^ Colorectal cancer and benign disease | Renal failure 5 (8/154) P=.79 Urinary retention 6 (9/154) P=.20 UTI 7 (11/154) P=.31 | Renal failure 5 (7/153) Urinary retention 10 (15/153) UTI 10 (16/153) | Pneumonia 5 (7/154) P=.79 Pleural effusion requiring drainage 3 (5/154) P=.47 | Pneumonia 5 (8/153) Pleural effusion requiring drainage 2 (3/153) | Cardiac arrhythmia 1 (2/154) P=.65 Pulmonary embolism 1 (2/154) P=.16 | Cardiac arrhythmia 2 (3/153) Pulmonary embolism 0 (0/153) | Respiratory complications requiring ICU (not specified) 1 (2/154) P=.16 Post-operative confusion 2 (3/154) P=.99 Intra-abdominal infection 7 (11/154) P=.22 | Respiratory complications requiring ICU 0 (0/153) Post-operative confusion 2 (3/153) Intra-abdominal infection 4 (6/153)

CVA=cerebral vascular accident; DVT=deep vein thrombosis; ICU=intensive care unit; UTI=urinary tract infection; NR=not reported; NS=not statistically significant

a Based on Delirium Rating Scale-Revised-98, Delirium was defined as the total score ≧18

b Calculated (Fisher's exact test)