# APPENDIX C PEER REVIEW COMMENTS/AUTHOR RESPONSES

Question | Reviewer's Response | Author's Responses
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Are the objectives, scope, and methods for this review clearly described? | Yes | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Is there any indication of bias in our synthesis of the evidence? | No | Thank you
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Thank you
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Thank you
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Thank you
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Thank you
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Thank you
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | No | Thank you
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | None | Thank you
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | Spelling: should read Morbidity on page 32 line 4 | This has been corrected.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | This is a well done systematic review of ERAS and colorectal surgery. Unfortunately most of the studies were of poor quality so the conclusions are weak. One element that is important to consider is the idea of ‘bundling’ and standardization and the benefit that this component of ERAS may have -- it was included in the HICPAC guidelines. | Thank you. We agree with the reviewer's comment about the quality of the studies. We added the concept of “bundling” to the “Implications for Practice” section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | This might not be appropriate for the purpose of this paper: My only suggestion would be that the VA could exploit the advantages of being a large system and come up with templated preadmission educational materials, CPRS notes/order sets and ways to facilitate obtaining CHO drinks preop for patients to facilitate adoption of this. These are items that I am currently working on-- could be adopted and edited by facilities as needed, but would help overcome a lot of the time barriers that we encounter. | Thank you for the suggestion. As the reviewer suspected, specific strategies for implementation are outside the scope of the review.