# APPENDIX B SEARCH STRATEGIES

MEDLINE (Ovid)

1 | ((fast and track) or fast-track or ERAS or ERP).mp.
2 | (enhanced and recovery and surg$).mp.
3 | (enhanced and recovery and program$).mp.
4 | ((multimodal or enhanced or accelerated) and (optimization or management or rehabilitation or protocol or package or program or pathway)).mp.
5 | 1 or 2 or 3 or 4
6 | (resection or surgical or surgically or surgery or laparo$ or procedure).mp.
7 | exp Colon/
8 | exp Rectum/
9 | exp Colon, Sigmoid/
10 | (bowel or rectal or colonic or colon or colorectal or rectum or sigmoid).mp.
11 | 7 or 8 or 9 or 10
12 | 6 and 11
13 | exp Colorectal Surgery/
14 | exp Rectum/su [Surgery]
15 | exp Colon/su [Surgery]
16 | 13 or 14 or 15
17 | 5 and 12
18 | 5 and 16
19 | 17 or 18
20 | limit 19 to (english language and yr="2011 -Current")

CINAHL

S1 | TX (fast and track) OR fast-track OR ERAS OR ERP OR (enhanced AND recovery AND (surg* OR program*)) OR ((multimodal OR enhanced OR accelerated) AND (optimization OR management OR rehabilitation OR protocol OR program OR pathway))
S2 | TX (resection OR surg* OR laparo* OR procedure)
S3 | TX (bowel OR rectal OR colonic OR colon OR colorectal OR rectum OR sigmoid)
S4 | S3 AND S3
S5 | S1 AND S4
S6 | S1 AND S4 (Published Date: 20110101-20161231)
S7 | S6 (English language)