# APPENDIX A CITATION OF INCLUDED RCTS AND CCTS IN PRIOR SYSTEMATIC REVIEWS OF ENHANCED RECOVERY IN COLORECTAL SURGERY (2011-2017)

| SYSTEMATIC REVIEWS (See Footnotes for Detailed Inclusion Criteria)
| Open or Open and Laparoscopic Surgery | | | | | | | | | | Laparoscopic Surgery Only
| Adamina 2011^5^ | Rawlinson 2011^13^ | Spanjersberg 2011^14^ | Lv 2012^12^ | Zhuang 2013^17^ | Bagnall 2014^a,6^ | Greco 2014^8^ | Grant 2017^7^ | Lau 2017^9^ | Launay-Savary 2017^a,10^ | Li 2013^11^ | Tan 2014^15^ | Zhao 2014^16^
RCTs Only | ✓ | | ✓ | ✓ | ✓ | | ✓ | ✓ | ✓ | | ✓ | ✓
Required number of components | ✓ | ✓ | ✓ | | ✓ | | | | ✓ | | ✓ | | ✓
Multiple languages allowed | ✓ | NR | ✓ | ✓ | ✓ | NR | ✓ | | | ✓ | | ✓
OPEN SURGERY STUDIES
Feng 2016^23^
Pappalardo 2016^31^
Jia 2014^a,27^ | | | | | | ✓ | | | ✓ | ✓
Nanavati 2014^30^ | | | | | | | | | ✓
Gouvas 2012^25^ (CCT)^b^ | | | | | | | | | | | | | ✓
Ren 2012^32^ | | | | | ✓ | | ✓ | | ✓
Wang 2012^b,35^ | | | | | | | ✓ | | ✓ | | ✓ | | ✓
Yang 2012^37^ | | | | | ✓ | | ✓ | | ✓
Vlug 2011^b,34^ | | | | ✓ | ✓ | | ✓ | | ✓ | | ✓ | ✓ | ✓
Wang 2011^36^ | | | | | | | ✓ | | ✓ | | ✓
Ionescu 2009^26^ | | | | | ✓ | | ✓ | | ✓
Muller 2009^29^ | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | | ✓
Šerclová 2009^33^ | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | | ✓
Khoo 2007^28^ | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | | ✓
Gatt 2005^24^ | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | | ✓
Anderson 2003^22^ | ✓ | ✓ | ✓ | ✓ | ✓ | | ✓ | | ✓
LAPAROSCOPIC SURGERY STUDIES
Ota 2017^42^ (CCT)
Scioscia 2017^43^
Mari 2016^40^
Wang 2015^45^ (CCT)
Feng 2014^38^ | | | | | | | | | ✓ | | | | ✓
Mari 2014^41^ | | | | | | | | | ✓
Gouvas 2012^25^ (CCT)^b^ | | | | | | | | | | | | | ✓
Wang 2012^b,35^ | | | | | | | ✓ | | | | ✓ | | ✓
Wang 2012^44^ | | | | | ✓ | | ✓ | | ✓ | | | ✓
Wang 2012^a,46^ | | | | | ✓ | ✓ | ✓ | | | ✓ | ✓ | ✓ | ✓
Vlug 2011^b,34^ | | | | ✓ | ✓ | | ✓ | | | | ✓ | ✓ | ✓
MIXED OPEN AND LAPAROSCOPIC SURGERY STUDIES
Forsmo 2016^50^

CCT=controlled clinical trial; RCT=randomized controlled clinical trial

a Elderly (≥65 years)

b 4-arm study: open surgery with enhanced recovery, open surgery with usual care, laparoscopic surgery with enhanced recovery, and laparoscopic surgery with usual care

Systematic Review Inclusion Criteria (Literature Search Dates)

Adamina 2011 (Search 1966 – June 2010): RCT comparing ERP with traditional care (any indication for colorectal surgery); adult population; minimum 30 day follow-up; documented compliance to ≥4 of 5 key components a) patient information, b) preservation of gastrointestinal function, c) minimizing organ dysfunction; d) active pain control; e) promotion of patient's autonomy); publication in English, German, French, Spanish, or Danish

Rawlinson 2011 (Search to February 2011): RCT or CCT with prospective intervention group that compared enhanced recovery perioperative program with traditional care; open or laparoscopic elective colorectal surgery (any indication); adult population; documented protocol with at least 4 components of enhanced recovery covering pre-, intra-, and postoperative periods); reporting at least one outcome of interest (length of stay, complications, readmission rates, mortality); language limitation not reported

Spanjersberg 2011 (Search 1990 – 2009): RCT comparing any type of enhanced recovery strategy for resections in colorectal disease to conventional recovery strategies; open or laparoscopic surgery; at least 7 enhanced recovery items in the intervention group and no more than 2 enhanced recovery items in the conventional care group; any language

Lv 2012 (Search 1966 – April 2012): RCTs comparing enhanced recovery with conventional perioperative care in major colorectal surgery (resection); minimum 30 day follow-up; any language

Zhuang 2013 (1966 – July 2012): RCTS comparing enhanced recovery with traditional care for elective colorectal surgery; open or laparoscopic surgery; malignant or benign disease; enhanced recovery program should include at least 7 of 20 components; adult population; reporting at least one outcome of interest (length of stay, readmission rates, complications, mortality); any language

Bagnall 2014 (1947 – February 2014): any study design; evaluating enhanced recovery program in elderly (65 years or older) population undergoing colorectal surgery (or with elderly cohort as a subgroup analysis); language limitation not reported

Greco 2014 (Search to June 2012): RCTs comparing enhanced recovery to standard treatment in colorectal surgery; no restriction on primary or secondary outcomes; any language

Grant 2017 (Search to June 2015): RCTs comparing enhanced recovery to standard care for perioperative care in adults undergoing general anesthesia for abdominal and pelvic surgery; reporting healthcare-associated infection; English language

Lau 2017 (1966 – February 2016): RCTs comparing enhanced recovery to standard care; age range not specified; any surgery (site or approach); enhanced recovery program included at least 4 components; reporting primary clinical outcomes (length of stay, 30-day readmission, 30-day mortality, total costs); English language abstract and/or full text

Launey-Savary 2017 (2000 – 2015): any study design; comparing feasibility of enhanced recovery in elderly (65 years or older) to younger population or to traditional management; elective colorectal surgery; reporting main endpoints (feasibility, efficacy, compliance); English or French

Li 2013 (Search to May 2013): RCTs (including abstracts) comparing laparoscopic colorectal surgery with enhanced recovery to laparoscopic colorectal surgery with conventional care; adult population; at least 7 of 17 enhanced recovery components; one month follow-up for complications and readmissions; reported at least one outcome of interest; English language

Tan 2014 (Search 1991 – February 2013): RCTs comparing enhanced recovery to traditional care in elective laparoscopic colorectal surgery; any language

Zhao 2014 (Search to April 2014): RCTs or CCTs comparing enhanced recovery with conventional care in laparoscopic colorectal cancer surgery; clear description of enhanced recovery protocol; applied at least 6 enhanced recovery components; reporting at least one outcome of interest (length of stay, time to first flatus, time of first bowel movement, complications, readmissions, mortality); English language