# References

1 Rui P, Kang K. National Hospital Ambulatory Medical Care Survey: 2014 Emergency Department Summary Tables. Available at: https://www.cdc.gov/nchs/ahcd/web_tables.htm. Accessed June 21, 2018.
2 Kelley K, Intrator O, Massey K, Edes T, Shay K, Allman RM. Veterans Health Administration Geriatrics & Extended Care Home and Community Based Programs. 21st International Association of Gerontology and Geriatrics World Congress: 2017, San Francisco, CA.
3 Sinha SK, Bessman ES, Flomenbaum N, Leff B. A systematic review and qualitative analysis to inform the development of a new emergency department-based geriatric case management model. Ann Emerg Med. 2011;57(6):672–682.21621093
4 Aminzadeh F, Dalziel WB. Older adults in the emergency department: a systematic review of patterns of use, adverse outcomes, and effectiveness of interventions. Ann Emerg Med. 2002;39(3):238–247.11867975
5 Keim S, Sanders A. Geriatric emergency department use and care. In: Meldon S, Ma OJ, Woolard R, eds. Geriatric Emergency Medicine. New York, NY: McGraw-Hill; 2004, pages 1–3.
6 Sanders AB, Morley JE. The older person and the emergency department. J Am Geriatr Soc. 1993;41(8):880–882.8340568
7 Preston LR, Chambers D, Campbell F, Cantrell A, Turner J, Goyder E. What evidence is there for the identification and management of frail older people in the emergency department? A systematic mapping review. National Institute for Health Research. Queen’s Printer and Controller of HMSO. 2017.
8 Schumacher JG. Emergency medicine and older adults: continuing challenges and opportunities. Am J Emerg Med. 2005;23(4):556–560.16032631
9 Baum SA, Rubenstein LZ. Old people in the emergency room: age-related differences in emergency department use and care. J Am Geriatr Soc. 1987;35(5):398–404.3571788
10 Grief CL. Patterns of ED use and perceptions of the elderly regarding their emergency care: a synthesis of recent research. J Emerg Nurs. 2003;29(2):122–126.12660693
11 Kahn JH, Magauran BG, Jr., Olshaker JS, Shankar KN. Current trends in geriatric emergency medicine. Emerg Med Clin North Am. 2016;34(3):435–452.27475008
12 Conroy SP, Stevens T, Parker SG, Gladman JR. A systematic review of comprehensive geriatric assessment to improve outcomes for frail older people being rapidly discharged from acute hospital: ‘interface geriatrics’. Age and Ageing. 2011;40(4):436–443.21616954
13 Fealy G, McCarron M, O’Neill D, . Effectiveness of gerontologically informed nursing assessment and referral interventions for older persons attending the emergency department: systematic review. J Adv Nurs. 2009;65(5):934–935.19399966
14 Jay S, Whittaker P, McIntosh J, Hadden N. Can consultant geriatrician led comprehensive geriatric assessment in the emergency department reduce hospital admission rates? A systematic review. Age and Ageing. 2017;46(3):366–372.27940568
15 Lowthian JA, McGinnes RA, Brand CA, Barker AL, Cameron PA. Discharging older patients from the emergency department effectively: a systematic review and meta-analysis. Age and Ageing. 2015;44(5):761–770.26265674
16 Carpenter CR, Bromley M, Caterino JM, . Optimal older adult emergency care: introducing multidisciplinary geriatric emergency department guidelines from the American College of Emergency Physicians, American Geriatrics Society, Emergency Nurses Association, and Society for Academic Emergency Medicine. Acad Emerg Med. 2014;21(7):806–809.25117158
17 Carpenter CR, Bromley M, Caterino JM, . Optimal older adult emergency care: introducing multidisciplinary geriatric emergency department guidelines from the American College of Emergency Physicians, American Geriatrics Society, Emergency Nurses Association, and Society for Academic Emergency Medicine. J Am Geriatr Soc. 2014;62(7):1360–1363.24890806
18 Carpenter CR, Bromley M, Caterino JM, . Optimal older adult emergency care: Introducing multidisciplinary geriatric emergency department guidelines from the American College of Emergency Physicians, American Geriatrics Society, Emergency Nurses Association, and Society for Academic Emergency Medicine. Ann Emerg Med. 2014;63(5):e1–3.24746436
19 Alberts MJ, Latchaw RE, Jagoda A, . Revised and updated recommendations for the establishment of primary stroke centers: a summary statement from the brain attack coalition. Stroke. 2011;42(9):2651–2665.21868727
20 PRISMA harms checklist: improving harms reporting in systematic reviews. BMJ. 2016;353.
21 Graf CE, Zekry D, Giannelli S, Michel JP, Chevalley T. Efficiency and applicability of comprehensive geriatric assessment in the emergency department: a systematic review. Aging Clin Exp Res. 2011;23(4):244–254.20930499
22 Bissett M, Cusick A, Lannin NA. Functional assessments utilised in emergency departments: a systematic review. Age and Ageing. 2013;42(2):163–172.23328756
23 Karam G, Radden Z, Berall LE, Cheng C, Gruneir A. Efficacy of emergency department-based interventions designed to reduce repeat visits and other adverse outcomes for older patients after discharge: A systematic review. Geriatr Gerontol Int. 2015;15(9):1107–1117.26171554
24 Schnitker L, Martin-Khan M, Beattie E, Gray L. What is the evidence to guide best practice for the management of older people with cognitive impairment presenting to emergency departments? A systematic review. Adv Emerg Nurs J. 2013;35(2):154–169.23636047
25 Hickman LD, Phillips JL, Newton PJ, Halcomb EJ, Al Abed N, Davidson PM. Multidisciplinary team interventions to optimise health outcomes for older people in acute care settings: A systematic review. Archives of Gerontology and Geriatrics. 2015;61(3):322–329.26255065
26 Leppin AL, Gionfriddo MR, Kessler M, . Preventing 30-day hospital readmissions: a systematic review and meta-analysis of randomized trials. JAMA Intern Med. 2014;174(7):1095–1107.24820131
27 Pines JM, Lotrecchiano GR, Zocchi MS, . A Conceptual Model for Episodes of Acute, Unscheduled Care. Ann Emerg Med. 2016;68(4):484–491e483.27397857
28 Gruneir A, Silver MJ, Rochon PA. Emergency department use by older adults: a literature review on trends, appropriateness, and consequences of unmet health care needs. Med Care Res Rev. 2011;68(2):131–155.20829235
29 EPOC. Effective Practice and Organisation of Care (EPOC). EPOC Resources for review authors. Oslo: Norwegian Knowledge Centre for the Health Services; 2015. Available at: http://epoc.cochrane.org/resources/epoc-resources-review-authors. Accessed November 3, 2017.
30 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177–188.3802833
31 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693–2710.12939780
32 Balshem H, Helfand M, Schunemann HJ, . GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. 2011;64(4):401–406.21208779
33 GRADEpro GDT. GRADEpro Guideline Development Tool [Software]. McMaster University, 2015 (developed by Evidence Prime, Inc.). Available from gradepro.org.
34 Basic D, Conforti DA. A prospective, randomised controlled trial of an aged care nurse intervention within the Emergency Department. Aust Health Rev. 2005;29(1):51–59.15683356
35 Biese K, Lamantia M, Shofer F, . A randomized trial exploring the effect of a telephone call follow-up on care plan compliance among older adults discharged home from the emergency department. Acad Emerg Med. 2014;21(2):188–195.24673675
36 Biese KJ, Busby-Whitehead J, Cai J, . Telephone follow-up for older adults discharged to home from the emergency department: a pragmatic randomized controlled trial. J Am Geriatr Soc. 2017.
37 Caplan GA, Williams AJ, Daly B, Abraham K. A randomized, controlled trial of comprehensive geriatric assessment and multidisciplinary intervention after discharge of elderly from the emergency department--the DEED II study. J Am Geriatr Soc. 2004;52(9):1417–1423.15341540
38 Eklund K, Wilhelmson K, Gustafsson H, Landahl S, Dahlin-Ivanoff S. One-year outcome of frailty indicators and activities of daily living following the randomised controlled trial: “Continuum of care for frail older people”. BMC Geriatr. 2013;13:76.23875866
39 Gagnon AJ, Schein C, McVey L, Bergman H. Randomized controlled trial of nurse case management of frail older people. J Am Geriatr Soc. 1999;47(9):1118–1124.10484257
40 McCusker J, Verdon J, Tousignant P, de Courval LP, Dendukuri N, Belzile E. Rapid emergency department intervention for older people reduces risk of functional decline: results of a multicenter randomized trial. J Am Geriatr Soc. 2001;49(10):1272–1281.11890484
41 Mion LC, Palmer RM, Meldon SW, . Case finding and referral model for emergency department elders: a randomized clinical trial. Ann Emerg Med. 2003;41(1):57–68.12514683
42 Runciman P, Currie CT, Nicol M, Green L, McKay V. Discharge of elderly people from an accident and emergency department: evaluation of health visitor follow-up. J Adv Nurs. 1996;24(4):711–718.8894888
43 Arendts G, Fitzhardinge S, Pronk K, Donaldson M, Hutton M, Nagree Y. The impact of early emergency department allied health intervention on admission rates in older people: a non-randomized clinical study. BMC Geriatr. 2012;12:8.22429561
44 Arendts G, Fitzhardinge S, Pronk K, Hutton M. Outcomes in older patients requiring comprehensive allied health care prior to discharge from the emergency department. Emerg Med Australas. 2013;25(2):127–131.23560962
45 Bond CM, Freiheit EA, Podruzny L, . The emergency to home project: impact of an emergency department care coordinator on hospital admission and emergency department utilization among seniors. Int J Emerg Med. 2014;7:18.24982694
46 Miller DK, Lewis LM, Nork MJ, Morley JE. Controlled trial of a geriatric case-finding and liaison service in an emergency department. J Am Geriatr Soc. 1996;44(5):513–520.8617898
47 Mortimer C, Emmerton L, Lum E. The impact of an aged care pharmacist in a department of emergency medicine. J Eval Clin Pract. 2011;17(3):478–485.21040247
48 Pedersen LH, Gregersen M, Barat I, Damsgaard EM. Early geriatric follow-up after discharge reduces readmissions – A quasi-randomised controlled trial. Eur Geriatr Med. 2016;7(5):443–448.
49 Adam GP, Springs S, Trikalinos T, . Does information from ClinicalTrials.gov increase transparency and reduce bias? Results from a five-report case series. Syst Rev. 2018;7(1):59.29661214
50 Robinson KA, Akinyede O, Dutta T, . Framework for Determining Research Gaps During Systematic Review: Evaluation. Methods Research Report. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 13-EHC019-EF. Rockville, MD: Agency for Health care Research and Quality. February 2013. Available at: https://www.ncbi.nlm.nih.gov/books/NBK126708/. Accessed June 12, 2018.
51 AHRQ Methods for Effective Health Care. In: Velentgas P, Dreyer NA, Nourjah P, Smith SR, Torchia MM, eds. Developing a Protocol for Observational Comparative Effectiveness Research: A User’s Guide. Rockville (MD): Agency for Healthcare Research and Quality (US); 2013.
52 Higgins JPT, Greene S, editors. Cochrane Handbook for Systematic Reviews of Interventions. The Cochrane Collaboration; 2011. Version 5.1.0 [updated March 2011]. Available at: http://training.cochrane.org/handbook. Accessed June 18, 2018.