# Summary and Discussion

We evaluated interventions to improve ED care for older adults, examining effects on a range of outcomes of importance to patients, clinicians, and policymakers. Our review is unique in the approach to classifying intervention strategies and specific components, careful ROB assessment, and the inclusion of randomized and stronger nonrandomized designs. We identified 9 randomized and 6 nonrandomized studies, all conducted in economically developed countries. Just over half of these enrolled high-risk older adults—patients that are medically similar to Veterans presenting to VA EDs. The interventions most commonly used case management or multiple intervention strategies. No studies were informed by an explicit conceptual model. When considering the interventions collectively, we found a small benefit on functional outcomes but no overall effect on ED readmission or subsequent hospitalizations. Although there was no overall effect on healthcare utilization, 2 studies with a more comprehensive intervention and longer duration of follow-up were associated with decreased healthcare utilization.^37,48^ Other outcomes were reported less frequently, and intervention effects could not be determined definitively.

We evaluated interventions applicable to a broad range of older adults, rather than focusing narrowly on condition-specific interventions. We were particularly interested in determining if specific strategies or intervention components were associated with greater benefit to older adults. Two strategies were evaluated infrequently (medication management) or not at all (guideline informed). Interventions evaluated were relatively low intensity (ie, short duration and limited number of planned patient contacts), and thus our findings are applicable only to low-intensity geriatric management interventions in the ED.

Strength of evidence (SOE) was rated for outcomes judged critical to decision making on the basis of study design, risk of bias (ROB), consistency, directness, and precision (Table 6). The SOE was rated high for effects on ED readmission. SOE was low or very low for all other outcomes. Concerns that contributed to the lower SOE were high ROB, inconsistent effects, and imprecision that was attributed to the 95% CI not excluding a small or small-to-moderate effect.

Table 6 Strength of Evidence for Effects of Interventions to Improve Outcomes for Older Adults in Emergency Departments

Outcome | Studies (Patients) | Findings | Strength of Evidence; (Rationale by Domain)
Physical function | Randomized: 5 (2233) | 3 of 5 showed benefit; beneficial interventions were multi-strategy | Very low SOE; (Serious ROB, inconsistent, imprecise)
Physical function | Nonrandomized: 1 (687) | No effect | Very low SOE; (Serious ROB, inconsistent, imprecise)
ED readmission | Randomized: 7 (4629) | Relative risk 1.13 (0.94 to 1.36) (9 fewer to 53 more per 1,000) | High SOE; (No serious ROB, consistent, precise)
ED readmission | Nonrandomized: 5 (6432) | 2 of 5 showed lower readmission; beneficial interventions were multi-strategy or case management | High SOE; (No serious ROB, consistent, precise)
Hospital admission after index | Randomized: 3 (3338) | Relative risk 0.96 (0.51 to 1.83) (59 fewer to 100 more per 1,000) | Low SOE; (No serious ROB, inconsistent, imprecise)
Hospital admission after index | Nonrandomized: 3 (5346) | No consistent effects on readmission | Low SOE; (No serious ROB, inconsistent, imprecise)
Patient experience | Randomized: 4 (1889) | 2 of 4 showed benefit for satisfaction, helpfulness, or self-esteem; beneficial interventions were multi-strategy or case management | Low SOE; (No serious ROB, consistent, indirect, imprecise)
Patient experience | Nonrandomized: 1 (199) | No usable data | Low SOE; (No serious ROB, consistent, indirect, imprecise)

Abbreviations: ROB=risk of bias; SOE=strength of evidence

## Findings in the Context of Prior Reviews

Most prior reviews focused on single strategies including case management,^3^ comprehensive geriatric consultation,^12^ nursing interventions,^13^ discharge planning,^15^ or risk-assessment tools.^22^ In contrast, our review included a broad range of intervention strategies as well as studies that used 1 or more intervention strategies. Only 1 of the prior reviews was published in the past 5 years (search date 2013) and judged of good quality.^15^ This review evaluated “community transition planning,” described as discharge planning in our review, and identified 9 studies. Consistent with our findings, they found no effect of discharge planning on utilization outcomes or mortality and found the evidence too limited to draw conclusions about effects on functional status.

An older systematic review of case management found that these interventions did not impact quality of life, but the evidence for this outcome was sparse.^3^ That review also carefully classified interventions and used qualitative case analyses to identify patterns but included studies at higher ROB, such as program descriptions and noncomparative observational studies. The review found that case management strategies utilizing multiple elements had a positive effect (defined inclusively as a positive effect on any outcome). The review was limited by the inclusion of study designs with high ROB and the lack of any careful quality or ROB assessment of the included studies. Across these reviews, general themes are that more comprehensive interventions are associated with greater effects, but that interventions tested to date do not show a consistent effect on utilization outcomes.

A recent good-quality evidence mapping review described a broad literature of studies examining risk-assessment tools and ED interventions for older adults.^7^ Evidence maps do not assess the quality of included studies, focusing instead on a description of the quantity and type of evidence, interventions, and outcomes reported. The authors found an extensive literature—much of it published only in meeting abstracts—and recommended formal literature syntheses.

## Clinical and Policy Implications

The diversity of interventions and outcome measures among included studies limits the ability to determine definitively the clinical utility of any single intervention strategy or set of intervention components. However, our structured approach to analyzing these heterogeneous findings, including careful examination of intervention components, suggests that future research could benefit from using a conceptual model to both guide a more comprehensive reporting of intervention components and enable researchers to analyze mechanisms of action. Some studies selected patients at higher risk for poor outcomes, but there was no clear relationship between intervention effects and selection of high-risk patients. Our findings suggest that multi-strategy, longitudinal interventions may be more effective than single-touch interventions isolated to the ED on improving clinical outcomes. ED interventions that bridge into more intensive outpatient management tended to reduce ED and hospital readmission rates as well as functional decline. From a clinical and policy perspective, these finding suggests that future research in this area may benefit from working across settings and disciplines. Furthermore, incorporating input from patients, family members, clinical staff, and policymakers representing both ED and post-ED community settings and services may help to identify and prioritize key outcomes.

Similar to previous reviews^23^ and the 2014 Geriatric Emergency Department Guidelines,^16–18^ our findings suggest that ED visits should not be considered in isolation, but rather as an integral part of the geriatric patient’s continuum of care, bridging inpatient and outpatient management. The patient’s functional status, access to community resources, and capacity for follow-up should be considered when planning their disposition. However, the relative benefit of individual interventions is unclear and requires further studies to elucidate.

## Limitations

Our protocol-driven review has several strengths, including input from an expert panel, a conceptual model, rigorous methods, and a structured approach to describing the key components of the tested interventions. This approach allowed for a theory-driven, standardized classification of the study interventions. A significant limitation of this approach is that intervention descriptions were not always detailed enough to describe some components with confidence. We limited our review to English-language publications, which may have excluded potentially informative evidence. Other limitations are described below.

### Publication Bias

Given the small number of studies, statistical methods to detect publication bias are not useful. We searched ClinicalTrials.gov for completed but unpublished studies, but this is not a particularly effective way to identify publication bias.^49^ Thus, although no publication bias was detected, tools for detection are poor.

### Study Quality

We were also limited by the existing literature. Of the 9 randomized studies, only 3 were evaluated as low ROB for objective outcomes. The most common limitation was lack of blinded outcome assessment. Almost all nonrandomized studies were judged high ROB for patient-reported outcomes and for objective outcomes. The basic study design, differences between intervention and control participants, and lack of analyses that adjusted for potential confounders were common problems. In addition, some key outcomes, such as quality of life, were infrequently reported. No studies reported adverse effects.

### Heterogeneity and Sparse Information

There was substantial diversity in study designs, including the choice to randomize and the intervention approaches. This made coherent synthesis and identification of themes difficult. Interventions typically did not specify a conceptual framework, and interventions differed substantially in goals, components, delivery, and intensity. Specifically, few studies reported detailed information on intervention strategies and components. This limited amount of information prevented us from conducting further analyses on patient- and provider-level intervention components. A lack of detail around patient characteristics, including medical history and presenting condition, further prevented us from mapping outcomes back to intervention strategies and predisposing characteristics, as depicted in our conceptual model. No studies used the 2014 Geriatric ED Guidelines^16–18^ to inform intervention development, and few studies explicitly addressed medication management.

### Applicability of Findings to the VA Population

None of the studies included Veteran samples. Seven studies were conducted in North America, and the others were conducted in economically developed countries. Thus, the staffing and training of ED staff and geriatric specialists should be broadly similar to VA EDs. Almost all Veterans have an assigned primary care provider, similar to studies conducted in countries with a national health service, and a health system that facilitates post-ED care. However, it is uncertain if the community and specialty care referral resources available to study patients were similar to those available to Veterans. Studies had a representative mix of men and women, but only 4 studies reported race; these studies had a representative mix of white and black patients. Few studies reported participants’ sociodemographic characteristics (ie, income, education), preventing us from abstracting this information, and further limiting the ability to evaluate the degree of sociodemographic similarities compared to Veteran populations. Most randomized studies excluded patients from long-term care facilities or individuals with important cognitive impairment. Therefore, results are most applicable to community-dwelling older adults without important cognitive impairment.

## Research Gaps/Future Research

We structured our analysis of gaps in evidence by considering each element of the PICOTS framework (Table 7).^50^ Although it would be possible to generate an extensive list of gaps in evidence, we restricted this list to the areas judged to be highest priority, given the current state of evidence. To facilitate future literature syntheses, we encourage investigators conducting clinical trials to include these studies in trial registries.

Table 7 Highest Priority Evidence Gaps

PICOTS Domain | Evidence Gap
Population | - No studies actively recruited Veterans.; - Few studies report clinical and sociodemographic characteristics of older adults using the ED, or subgroup (interaction) effects, limiting the ability to examine whether effects of interventions may vary across different clinical or demographic subgroups.; - Although some studies recruited high-risk older adults, it is unclear which subgroups of older adults are most likely to benefit from geriatric ED interventions.
Interventions | - No studies included a conceptual model to guide selection of intervention strategies and components or propose relationships between intervention strategies and study outcomes. Most interventions did not explicitly address domains such as unmet biopsychosocial and/or psychological needs.; - Limited reporting around intervention strategies and components make it difficult to identify the relationship between intervention structure and outcomes.; - Few studies included elements of caregiver education or support.; - Limited information makes it difficult to identify the optimal dose of ED interventions (eg, number of contacts, frequency and duration of contacts, overall length of intervention).; - To date, no studies have evaluated interventions guided by the 2014 Geriatric ED Guidelines.
Comparators | - Additional research is needed to identify effective intervention strategies and components before undertaking head-to-head comparison of different intervention types, doses, or modalities.
Outcomes | - Lack of a uniform, core set of patient/stakeholder prioritized outcomes limits comparisons across studies.
Timing | - The optimal time to assess significant changes in clinical and utilization outcomes for ED-based interventions is unknown.
Setting | - Interventions that “bridge” pre- and post-ED care, meaning those that include contacts both before and after discharge, may be most effective. However, additional information is needed around the timing and coordination of care within these interventions.; - There is limited information on interventions taking place in large, integrated healthcare systems similar to VA healthcare system.

Abbreviations: ED=emergency department; VA=Veterans Affairs

Given its integrated structure, including presence of a primary care medical home (ie, patient-aligned care team, or PACT), high proportion of complex patients, and continuum of available Geriatrics and Extended Care services (ie, ambulatory care, inpatient care, home and community-based long-term services and supports, and facility-based care), VA is an ideal setting to pursue additional research in geriatric emergency medicine and address some of the evidence gaps noted above. In considering future research, we recommend considerations across several major domains as follows.

### Conceptual Model/Framework

A more holistic model describing multilevel factors that influence older ED use and resulting clinical and utilization outcomes may help to guide the selection of intervention strategies and explore how particular strategies do or do not address unmet needs and other determinants of ED use. A conceptual model can also be used to hypothesize and evaluate relationships between determinants of ED use, intervention strategies, and outcomes of interest. Further, the conceptual model should expand beyond medical/clinical factors influencing ED use to also acknowledge social determinants of health, personal preferences, and access to care. Interventions guided by a conceptual model may help researchers better identify subgroups of high-risk patients who may benefit the most from ED interventions. The use of a conceptual model also may motivate more complete data collection and reporting, including details on participant characteristics (ie, sociodemographics) as well as intervention strategies and components. The availability of such data, combined with hypothesized relationships outlined in a conceptual model, may allow researchers to better understand the mechanisms through which selected intervention strategies influence key outcomes.

### Innovation in Intervention and Study Design

An inherent challenge in developing and evaluating ED intervention strategies is to balance the need for broad interventions that are applicable for a diverse patient population while also recognizing that patient-centered interventions or those designed for high-risk subgroups may be most effective. Adaptive interventions, including those that optimize delivery by tailoring the dose and content of an intervention to each individual, may help to maximize intervention effects. Research methods and study designs must be appropriate for these emerging intervention designs. Traditional randomized trials prevent researchers from isolating intervention components and identifying which individual components may be associated with intervention effects. Incorporating alternative frameworks, including factorial designs, to the intervention development process may enable researchers to not only examine average treatment effects but also disentangle the relative contribution of individual intervention strategies and combinations of intervention components. Hybrid designs enable researchers to simultaneously explore intervention and implementation effects.

### Outcomes and Measurement

Several measurement challenges should be resolved before conducting additional research. First, utilization outcomes, including hospitalization and ED readmission, have been studied most frequently in prior ED studies. However, important clinical and utilization outcomes may have been overlooked. For example, clinical outcomes such as functional status, psychological health, and improved chronic disease self-management may impact health status while access to or use of primary care and specialty services may impact both health and acute care utilization. Second, the heterogeneity of older ED users requires use of more general, compared to disease-specific, outcome measures. However, their responsiveness to ED strategies may be limited and may not fully capture important states or concerns related to an ED visit. Third, it is essential to select measures, particularly those related to physical function, that lack floor or ceiling effects and are sufficiently responsive to changes in older, complex patient populations. Given these considerations, there is a substantial opportunity for patient- and stakeholder-engaged research, such as that prioritized by VA and the Patient-Centered Outcomes Research Institute.

### Geriatric Emergency Department Guidelines

As noted, no studies were guided by the 2014 Geriatric ED Guidelines. However, this is not unexpected given the time needed to gain awareness of such guidelines, implement changes, evaluate results, and disseminate findings. These guidelines provide a template for developing geriatric-friendly EDs, giving particular emphasis to elements that may enhance the care experience and improve outcomes for older adults. Although not reported in our results, we identified many of these elements as being present in the included studies, including the use of a geriatric-trained physician or nurse, interdisciplinary team, referrals or partnerships with community services, and care coordination strategies (eg, interdisciplinary team meeting). Future research may consider these guidelines to inform conceptual models and/or research interventions.

## Conclusions

We focused only on studies recruiting general patient populations as opposed to focusing on interventions for specific presenting conditions or diagnoses upon ED discharge (eg, falls, heart failure). Our results indicate mixed effects of ED intervention strategies on select clinical and utilization outcomes. The small number of studies using any single intervention strategy makes it difficult to draw definitive conclusions because of imprecise estimates of effect and variability in study populations, intervention strategies, and intervention components. However, we found evidence that studies evaluating multi-strategy interventions and those with a more intensive structure, as indicated by the presence of three key intervention components (ie, assessment, referral plus follow-up, and planned contacts both pre- and post-ED discharge) may be associated with a small benefit in functional status, decreased hospitalization after the ED index visit, and/or lower likelihood of ED readmission. Future research should be informed by a comprehensive conceptual model, consider emerging intervention approaches (eg, adaptive, or dynamic, treatment designs), employ rigorous evaluation strategies, adhere to more thorough reporting of intervention structure, and engage patients and relevant policymakers in selecting outcomes of interest.