# Results

## Literature Flow

We identified 1,799 studies through searches of MEDLINE^®^ (via PubMed^®^), Embase^®^, and CINAHL. An additional 79 articles were identified by reviewing the bibliographies of relevant review articles,^7,12–15^ a search of ClinicalTrials.gov, and a targeted search of Scopus for publications citing the 2014 Geriatric ED Guidelines,^18^ for a total of 1,878 unique citations (Figure 2). After applying inclusion and exclusion criteria to titles and abstracts, 100 articles remained. Seventeen articles, describing 15 unique studies, met eligibility criteria and were retained for data abstraction. Of the 15 studies, 9 were randomized and 6 were nonrandomized. All were conducted in the United States, Canada, Europe, or Australia.

Figure 2 Literature Flow Chart

* Unique citations after combining all searches and manual bibliography review

## Key Question: How effective are emergency department (ED) interventions in improving clinical, patient experience, and utilization outcomes in older adults (age ≥65)?

## Key Points

- The literature addressing intervention strategies for older adults presenting to EDs is diverse, with varying approaches to selecting patients for services and an array of intervention strategies that typically incorporate geriatric care and/or chronic care principles that have been effective in other settings.
- ED interventions showed a mixed pattern of effects on clinical outcomes. Evidence suggested a small benefit for functional status (very low SOE), but no effects on quality of life (QOL). However, only 2 studies reported effects on QOL.
- ED interventions did not show a reduction in mortality, but no study identified mortality as a primary outcome. This finding was based on few events, and confidence intervals do not exclude an important effect.
- Overall, there were no effects of ED interventions on hospitalization at the index visit (very low SOE), subsequent hospitalizations (low SOE), or ED readmission (high SOE).
- Studies with the greatest effects on clinical and health care utilization outcomes employed more comprehensive interventions, but this pattern was not consistent across all effective interventions:
  ○ Multi-strategy interventions, defined as those using more than 1 intervention strategy (eg, discharge planning, case management, medication management), may be associated with less decline in functional independence.
  ○ More intensive, or higher touch, interventions, as indicated by the presence of 3 key intervention components (ie, assessment, referral plus follow-up, and bridge design), may be associated with less decline in functional independence, and decreased hospitalization after the ED index visit and/or ED readmissions.
  ○ Single-contact interventions, whether delivered in the ED or after discharge, do not improve utilization outcomes.

## Detailed Findings

### Description of Included Studies for ED Interventions for Older Adults

We identified 9 randomized studies^34–42^ and 6 nonrandomized studies^43–48^ that evaluated interventions to improve the outcomes of older adults who present for care in an ED. Studies recruited a broad patient population (ie, not limited to a specific diagnosis or condition). No studies enrolled mixed samples of younger and older patients. Just over one-half of the studies enrolled older adults at higher risk for poor health outcomes as determined by either a risk-assessment tool or clinical criteria (eg, dependent in 1 or more activities of daily living [ADLs]). The remainder of the studies included unselected older adults. No studies specified enrollment of Veterans. All studies compared an intervention to usual care or attention control. Interventions were delivered during the index ED visit, post-ED discharge, or across settings (ie, bridge). Case management was the most common intervention strategy (n=12), followed by discharge planning (n=7), and medication management/medication safety (n=3). Roughly one-half of studies (n=7) used more than 1 intervention strategy and thus were classified as “multi-strategy.” The most common combinations were discharge planning plus case management (n=5) and case management plus medication safety (n=2). Tables 3 and 4 show the pattern of interventions, classified by strategy and components.

Table 3 Randomized Studies (n=9)

Intervention Strategy (# Studies) | Components
Intervention Strategy (# Studies) | Assessment | Referral Plus Follow-up | Bridge
Discharge planning (n=0) | – | – | –
Case management (n=4) | 4 | 1 | 1
Medication safety (n=0) | – | – | –
Geriatric EDs (n=0) | – | – | –
Multi-strategy (n=5) | 3 | 4 | 3

Table 4 Nonrandomized Studies (n=6)

Intervention Strategy (# Studies) | Components
Intervention Strategy (# Studies) | Assessment | Referral Plus Follow-up | Bridge
Discharge planning (n=2) | 2 | 0 | 0
Case management (n=1) | 1 | 1 | 0
Medication safety (n=1) | 0 | 0 | 0
Geriatric EDs (n=0) | – | – | –
Multi-strategy (n=2) | 2 | 0 | 1

Across the strategies, interventions included the components of risk assessment (n=12, including 8 that specified use of a comprehensive geriatric assessment), referral plus follow-up (n=6), and bridge designs (n=5). All 3 of these intervention components were present in 4 of the randomized studies. The number of team members involved in a single intervention ranged from 1 to 4, and included physicians, nurses, social workers or case managers, and physical or occupational therapists. Eight studies used a geriatrician, geriatric nurse provider, or other provider with geriatrics training. The number of planned contacts was reported in only 8 of the 15 studies, with 6 of these reporting 1 planned contact.

Measures of healthcare utilization, such as ED readmission, were the most commonly reported outcomes. Effects on physical functioning were reported in almost half the studies; QOL was reported in only 2 studies. The ROB for objective outcomes was judged low for 4 studies,^37,40,41,48^ unclear for 3,^36,39,42^ and high for 7^34,35,43–47^; 1^38^ study did not report an objective outcome. The ROB for patient-reported outcomes was judged low for 2 studies,^40,41^ unclear for 3,^37,39,42^ and high for 6^34–36,38,46,47^; 4 studies^43–45,48^ did not report patient-reported outcomes. Demographic factors were reported infrequently, including race, socioeconomic status, and insurance status. Seven randomized and 5 nonrandomized studies described the most common presenting condition or discharge diagnosis, but used variable methods for classifying them. All studies were conducted in the United States, Canada, Europe, or Australia between 1996 and 2017. The comparators for all studies were treatment as usual.

Table 5 shows the evidence profile for the included studies.

Table 5 Evidence Profile for Emergency Department Interventions for Older Adults

| Randomized (n=9) | Nonrandomized (n=6)
Study designs | 8 randomized studies; 1 cluster-randomized study | 5 nonrandomized studies; 1 controlled before-after study
Number of patients | 4,561 | 11,580
Patient eligibility | 4 high-risk patients only; 5 unselected older adults | 4 high-risk patients only; 2 unselected older adults
Exclusion criteria | 3 need for immediate treatment; 6 long-term care facility; 5 cognitive impairment | 3 need for immediate treatment; 0 long-term care facility; 1 cognitive impairment
Median patient age (range) | 79 (74-82); (1 study NR) | 78.5 (75-86)
Patient sex (%) | 59% women | 59% women
Race (%) | 64% white (6 studies NR); 25% black | 67% white (5 studies NR); 32% black
Patients with cognitive impairment^a^ | 27.3% (5 studies NR) | 8.5% (5 studies NR)
Patients’ living status (%) | 789/4688 (16.8%) living alone; (5 studies NR) | 3072/11580 (26.5%) living alone; (2 studies NR)
Patient has primary care^b^ | 88% (8 studies NR) | NR
Intervention strategy^c^ | 3 discharge planning; 9 case management; 2 medication safety; 0 geriatric EDs | 4 discharge planning; 3 care management; 1 medication management; 0 geriatric EDs
Multi-strategy interventions | 5 studies | 2 studies
Major intervention components^c^ | 7 assessment; 5 referral plus follow-up; 4 bridge design^d^ | 5 assessment; 1 referral plus follow-up; 1 bridge design^d^
Outcomes reported | 7 ED readmission; 6 functional status; 5 hospitalization after ED discharge; 4 patient experience; 2 quality of life; 3 mortality; 2 hospitalization at ED index | 5 ED readmission; 1 functional status; 3 mortality; 3 hospitalization after ED discharge; 1 patient experience; 2 hospitalization at ED index; 1 quality of life
Risk of bias for objective and patient-reported outcomes | Objective:; - 2 high risk; - 3 unclear risk; - 3 low risk; - 1 NA; Patient-reported:; - 4 high risk; - 3 unclear risk; - 2 low risk | Objective:; - 5 high risk; - 1 low risk; Patient-reported:; - 2 high risk; - 4 NA

a Definitions of impairment varied from abnormal cognitive screen to dementia to delirium/confusion.

b 6 randomized and 5 nonrandomized studies were conducted in countries with National Health Service.

c Numbers sum to more than 15 because studies employed more than 1 intervention type.

d Design refers to interventions that include contact both within the ED and after discharge.

Abbreviations: ED=emergency department; NA=not applicable; NR=not reported

### Summary of Findings

Next, we organize the findings from the 15 ED intervention studies by effects on (1) clinical outcomes of functional status, QOL, and mortality; (2) patient experience outcomes; and (3) utilization outcomes. We describe results from randomized studies first, as these are more likely to report valid estimates of intervention effects. Because of the small number of studies reporting outcomes that used comparable measures, we conducted meta-analyses only for randomized studies reporting hospitalization after the index visit and ED readmission. Other outcomes are synthesized qualitatively, giving more weight to larger studies with a lower ROB. In some cases, results are grouped by how outcomes were measured (eg, hospitalization as dichotomous outcome followed by hospitalization length of stay).

Appendix F presents detailed study characteristics; Appendix G provides detailed intervention characteristics; Appendix H lists the excluded studies and reasons for exclusion; and Appendix I contains a glossary of terms.

## Effects on Clinical Outcomes

### Functional Status

A total of 6 studies, of which were 5 randomized, evaluated the effect of ED interventions on functional status using a variety of outcome measures and analysis approaches.^37–40,42,46^ Functional status was a primary outcome in all but 1 study^37^ and was evaluated using measures of ADLs or independent ADLs (IADLs), reported categorically (eg, dependent ADLs) or using a continuous scale. Three randomized studies evaluated single-strategy interventions of case management.^37,39,42^ Three studies, including 2 randomized^38,40^ and 1 nonrandomized,^46^ evaluated multi-strategy interventions, all using discharge planning plus case management. Positive intervention effects were observed in 4 of the 5 randomized studies,^37,38,40,42^ and of these, 2 focused on high-risk older adults and included all 3 intervention components of interest (ie, assessment, referral plus follow-up, and bridge).^38,40^ Two other randomized studies recruited unselected older adults; 1 included all 3 intervention components and also followed participants for up to 4 weeks,^37^ while the second included only 1 intervention component (assessment).^42^ Findings of individual randomized studies are described below, focusing first on those reporting categorical changes in function, then those reporting functional status as a continuous outcome.

Three randomized studies defined functional status as changes in dependence in ADLs/IADLs; all found positive effects.^38,40,42^ One moderate-sized, low ROB study evaluating a multi-strategy intervention (ie, discharge planning plus case management) found a statistically significant lower odds of clinically important functional dependency, defined as less decline in ADLs/IADLs (odds ratio [OR] 0.53; 95% CI 0.31 to 0.91) at 3 and 4 months, respectively.^40^ A second small, high ROB study evaluating discharge planning plus case management found a significantly greater odds of functional improvement, as defined by improvement in ADL performance on the staircase measured at 3 months (OR 2.37; 95% CI 1.20 to 4.68) and 12 months (OR 2.04; 95% CI 1.03 to 4.06).^38^ Both studies recruited high-risk populations and evaluated interventions with all 3 intervention components present. A third moderate-sized study with unclear ROB evaluated case management and found that intervention participants reported higher levels of functional independence in IADLs compared with the control group (p=0.027), but there were no significant differences in ADL independence (p=0.47).^42^

Two randomized studies evaluated change in functional status, reporting the Barthel Index of ADLs and Older Americans Resources and Services (OARS) as a continuous outcome.^37,39^ One study with a relatively small sample size (N=427) and unclear ROB recruited a high-risk population of older adults who were admitted to the hospital in the prior 12 months and evaluated case management (ie, referral to community services) delivered after ED discharge.^39^ There were no differences in ADL or IADL mean scores between intervention and control groups. A second study with moderate sample size (N=739) and unclear ROB evaluated case management delivered pre- and post-ED discharge, and found that intervention participants reported less functional decline at 6 months compared with control (-0.25 intervention vs −0.75 decline; p<0.001).^37^ At 18 months, there were no significant differences in the rate of functional decline between intervention and control groups. This intervention included all 3 components including follow-up by intervention staff for up to 4 weeks after study enrollment.

One nonrandomized study with a moderate sample size and high ROB evaluated a multi-strategy intervention (ie, discharge planning plus case management) and examined the number of older adults reporting basic and intermediate dependency in ADLs based on the Katz scale.^46^ The number of participants reporting each level of dependency at 3 months was similar for intervention and control groups, although no statistical tests were presented.

### Quality of Life

Three studies^39,41,46^ (2 randomized) evaluated the effects of ED interventions on QOL—1 of multiple primary outcomes in 2 studies.^39,46^ One study evaluated case management^39^ while 2 studies^41,46^ (1 randomized) evaluated multi-strategy interventions (ie, discharge plus case management). The 2 studies evaluating multi-strategy interventions included all 3 intervention components.^41,46^ Results are sparse for this outcome, but based on limited data do not suggest an intervention effect.

Two randomized studies reported physical and mental health-related QOL using the SF-36 physical function and mental health component scores.^39,41^ One study, judged unclear ROB, recruited high-risk older adults and evaluated a case management intervention with assessment only.^39^ The second, judged low ROB, recruited unselected older adults and evaluated a discharge plus case management intervention with all 3 intervention components.^41^ Assessment time points included 30 and 120 days^41^ and 10 months.^39^ There were no statistically significant effects of the ED interventions on either physical or mental health-related QOL at any time point. Although there was no significant effect on QOL, results favored the intervention.

One nonrandomized study reported an unadjusted analysis of QOL at 3 months using a single item drawn from a validated scale.^46^ Scores were similar for intervention and control participants, yet there was not sufficient information reported to conduct an analysis.

### Mortality

Six studies evaluated the effect of ED interventions on mortality based on data in the electronic health record (EHR).^36,37,41,44,46,48^ Mortality was a primary outcome in 3 nonrandomized studies^44,46,48^; no randomized studies included mortality as a primary outcome. Two studies evaluated single intervention types, including discharge planning (n=1, nonrandomized)^44^ and case management (n=2, including 1 randomized).^37,48^ Four studies evaluated multi-strategy interventions, 3 consisting of discharge planning plus case management^40,41,46^ and 1 case management plus medication safety.^36^ Two randomized studies and 1 nonrandomized study included all 3 intervention components.^37,41,46^ The overall pattern of results suggests no effect on mortality, but no studies had a large enough sample and number of events to exclude a clinically important effect.

Three randomized studies evaluated the effect of ED interventions on mortality (Figure 3).^36,37,41^ Two were judged low ROB^37,41^ and 1 high ROB.^36^ All 3 studies recruited unselected older adults. The studies varied in their assessment time points, ranging from 30 days^36,37,41^ to 180 days.^37^ There was no significant effect of the ED interventions on mortality. Two of the 3 studies had few deaths (proportion of deaths in intervention and control groups: 0% to 1%), with resulting imprecise estimates indicated by wide confidence intervals (CIs).

Figure 3 Forest Plot of Effect of ED Interventions on Mortality^a^ a No summary estimate of effect is reported for the randomized studies due to the highly variable timing of the assessment, and for nonrandomized studies due to the small number of studies and high ROB.

Abbreviations: CI=confidence interval; DC=discharge; ED=emergency department

Three nonrandomized studies evaluated the effect of ED interventions on mortality.^44,46,48^ Two recruited high-risk older adults. Only 1 study, judged low ROB, reported an adequately adjusted analysis.^48^ The studies varied in their assessment time points, ranging from 28 days^44^ to 30 days^46^ to 3 months.^48^ There were no significant effects of the ED interventions on relative risk of mortality.

## Effects on Patient Experience Outcomes

Five studies evaluated the effect of ED interventions on patient experience based on a range of outcome measures, including the Client Satisfaction Questionnaire, Satisfaction with Care Scale, and 2 unnamed scales in which items were drawn from existing instruments.^39–42,47^ Patient experience was not included as a primary outcome in any studies. The randomized studies were judged low ROB (n=2)^40,41^ and unclear ROB (n=2),^39,42^ while the single nonrandomized study was judged high ROB.^47^ Interventions assessed were case management (n=2, both randomized^39,42^) and medication safety (n=1, nonrandomized^47^). Two studies evaluated multi-strategy interventions consisting of discharge planning plus case management.^40,41^ Overall, these studies show a mixed pattern, with 2 of the 5 studies reporting higher satisfaction with care or greater patient knowledge of community resources. Findings of individual studies are described below.

Two randomized studies evaluated patient satisfaction with care using continuous outcome measures, Client Satisfaction Questionnaire and Satisfaction with Care Scale.^39,40^ Both studies had small to moderate sample sizes and were judged unclear and low ROB. Assessment time points occurred at 1 month and 10 months. There were no statistically significant effects of the ED interventions on patient experience in either study, although results favored the intervention. A third study of moderate sample size (N=650) and low ROB evaluated multi-strategy interventions and included all 3 intervention components.^41^ This study reported mean satisfaction values from a single item that assessed satisfaction with the information received about agencies or organizations to help with needs after leaving the ED, and was included as part of routine ED care. Using a 5-point Likert Scale (1=poor to 5=excellent), this study found a significant difference between intervention and control participants in level of satisfaction regarding information received while in the ED (3.42 vs 3.03; MD 0.37; 95% CI 0.13 to 0.62). A fourth randomized study with a small sample size and unclear ROB evaluated satisfaction with care 4 weeks after the intervention utilizing an unnamed instrument and found that 40% of intervention participants recalled helpful interventions while 28% reported benefits of improved confidence and self-esteem.^42^

One nonrandomized study with a small sample size and high ROB evaluated patient satisfaction with a care provider using a 13-item survey drawn from a validated questionnaire.^47^ However, no summary or average scores were reported; thus no conclusions could be drawn from this outcome.

## Effects on Utilization Outcomes

### Hospitalization at the ED Index Visit

Four studies (2 randomized) examined the effect of hospitalization at the index ED visit,^34,40,43,45^ 3 of which included this as a primary outcome.^34,43,45^ All 4 studies reported hospitalization at the index visit as a dichotomous variable. Data regarding admission versus discharge disposition were collected prospectively. Interventions included discharge planning (n=1),^43^ case management (n=1),^34^ and 2 multi-strategy interventions consisting of discharge planning plus case management (n=2).^40,45^ All interventions were delivered in the ED prior to discharge. Only 1 study included all 3 intervention components.^40^ Overall, only 1 nonrandomized study showed a benefit of ED interventions on hospitalization at the index visit.^43^

The 2 randomized studies recruited high-risk older adults and used intervention components that included geriatric assessments^34^ and risk assessments plus referrals and follow-up.^40^ In 1 study, anticipated admission was an exclusion criteria, and therefore this study had a very small number of admitted participants, 14 of 178 in the intervention group and 26 of 210 in the control group.^40^ The second study had a very high admission rate of 76%.^34^ Participants in this study were specifically referred to an “aged care” nurse, and randomization occurred after a detailed baseline assessment.

Two large nonrandomized studies were both judged high ROB.^43,45^ Both enrolled high-risk older adults. Both included an assessment, but only 1 also included referral to community services.^45^ One included older adults who resided in nursing homes, although these patients made up <20% of the sample.^45^ One study used propensity scores to appropriately adjust for nonrandomization and found a lower admission rate in older adults receiving discharge planning (OR 0.88; 95% CI 0.76 to 1.0).^43^ However, admission to the ED observation unit and deaths in the ED were also categorized as admissions. In a subgroup analysis, older adults whose presenting problem was musculoskeletal symptoms or angina had lower admission rates. However, those subgroup analyses were performed post hoc and should be considered exploratory. The second nonrandomized study had poor matching between the intervention and control groups.^45^ There were no effects on admission rates overall, or when comparing only those cases with high matching.

### Hospitalization after the ED Index Visit

Eight studies reported effects of ED interventions on hospitalization after the index ED visit,^36,37,39,41,42,44–46^ including 5 randomized studies.^35–37,39,41^ Three studies evaluated single intervention strategies including discharge planning (n=1)^44^ and case management (n=2).^37,39^ Five studies evaluated multi-strategy interventions including discharge planning plus case management (n=3)^41,45,46^ and case management plus medication management (n=2).^35,36^ Three randomized studies included all 3 intervention components.^37,41,46^

Three moderate to large randomized studies reported hospitalization as a dichotomous outcome.^36,37,41^ It was a primary outcome for 2 of these studies, both of which had a low ROB.^37,41^ All 3 studies targeted unselected older adults. One study evaluated case management^37^ while 2 studies evaluated multi-strategy interventions, including case managing plus discharge planning^41^ and case management plus medication safety.^36^ Outcomes were assessed by patient report, with confirmation via EHR.^36,37,41^ Overall, there was no intervention effect (RR 0.96; 95% CI 0.51 to 1.83, Figure 4), but the confidence interval was wide and intervention effects varied significantly (Q=5.4, p=0.07; I^2^=63%). When looking at the effects reported by individual studies, 2 found no impact on hospitalization at 30 days.^36,41^ One of these studies included all 3 intervention components.^41^ The other had none of the intervention components hypothesized to be important.^36^ Two studies had prolonged follow-up periods of 120 days and 18 months.^37,41^ One found a decreased risk of hospitalization at each of the follow-up time points, with a reported number needed to treat of 18 to prevent 1 hospitalization at 30 days, and a number needed to treat of 10 to prevent 1 hospital admission at 18 months.^37^ An analysis of time-to-first-emergency hospitalization as a continuous variable also showed an intervention benefit. This study included all 3 intervention components and had the most intensive intervention of the included studies, with presentation of each case at a weekly interdisciplinary conference and ongoing involvement of the intervention team for up to 4 weeks after the index ED visit.

Figure 4 Forest Plot of Effect of ED Interventions on Hospitalization After the Index Visit^a^ a No summary estimate of effect is reported for nonrandomized studies because of the small number of studies and high ROB.

Abbreviations: CI=confidence interval; DC=discharge; ED=emergency department

Three randomized studies also reported hospitalization after the ED index visit using a variety of continuous outcome measures.^37,39,41^ One was judged unclear ROB^39^ and 2 low ROB.^37,41^ Two studies evaluated case management.^37,39^ One study evaluated a multi-strategy intervention consisting of discharge planning plus case management.^41^ Only 1 study, which used all 3 intervention components, found a significant effect of the intervention on hospitalization after the ED index, detailed in the above section.^37^ Another study, which also included all 3 intervention components, reported the number of subsequent hospital days at follow-up time points of 30 and 120 days.^41^ There was no difference between the intervention and control groups. The last study reported the mean number of admissions at 10 months’ follow-up, with no difference between groups.^39^ Only 1 intervention component, a comprehensive assessment, was used in this study. Participants were initially enrolled in the study if they had been discharged from the ED in the previous 12 months. This study aimed to enroll high-risk older adults,^39^ while the other 2 enrolled unselected older adults.^37,41^

Four nonrandomized studies reported hospitalization after the index visit: 3 using a dichotomous outcome^44,45,48^ and 1 using a continuous measure.^46^ A low ROB study that enrolled high-risk older adults evaluated case management and included all 3 intervention components.^48^ This study found a lower likelihood of hospitalization at 30 days (RR 0.55; 95% CI 0.36 to 0.82). In this study, a statistically significant higher percentage of participants in the intervention group were discharged to home at the index ED visit and had a longer length of sustained contact with the geriatric ED team than did those in the control group (14 days as opposed to 1 day). A high ROB study that evaluated discharge planning and included only 1 intervention component, assessment, found that intervention participants had a higher risk of hospitalization at 1 year.^44^ The matching used for this study involved matching a high-risk intervention participant with a low-risk control participant. Risk was determined using a 4-question screening tool, and a positive answer to any question led to a high-risk designation. The last 2 studies evaluated case management plus discharge planning. Another study also used pair matching that was not robust; it found no effect on hospitalization.^45^ This study included only 1 intervention component, assessment.^45^ A final study reported hospitalization after the index visit as a continuous measure.^46^ This prospective cohort study matched pairs only by age and gender and over one-half were admitted to the hospital at the index visit. There was no difference in number of nights spent in the hospital between the intervention and control groups. This held true even when performing subanalysis on participants who were discharged to home at the index visit. Only 1 intervention component, assessment, was used in this study.

### Emergency Department Readmission

Twelve studies (7 randomized) reported ED readmission after the index ED visit using a variety of methods and data sources including patient report and EHR data.^35–37,39–42,44–48^ Six randomized studies reported ED readmission as a dichotomous outcome,^35–37,40–42^ but this was a primary outcome in just 2 studies.^36,41^ One study reported a composite outcome of ED readmission and hospitalization after the index visit.^35^ When queried, the author reported that a majority of these visits were ED readmissions, although a breakdown of numbers could not be provided. Six studies evaluated single-type intervention strategies including case management (n=4; 3 randomized^37,39,42,48^), discharge planning (n=1; nonrandomized^44^), and medication safety (n=1; nonrandomized^47^). Six studies evaluated multi-strategy interventions including discharge planning plus case management (n=4)^40,41,45,46^ and case management plus medication management (n=2).^35,36^ All 3 intervention components were present in 3 randomized studies^37,40,41^ and 1 nonrandomized study.^46^ Overall, these interventions did not decrease ED readmission.

When considered altogether, the randomized studies that reported ED readmission as a dichotomous outcome found no effect on ED readmission (RR 1.13; 95% CI 0.94 to 1.36, Figure 5).^35–37,41,42^ As described above, 2 studies evaluated single-strategy interventions of case management^37,42^ while 3 studies evaluated multi-strategy interventions of case management plus medication safety and discharge planning plus case management.^35,36,41^ However, patients in the case management plus medication management studies were identified days after ED discharge and the interventions were delivered via a single phone call.^35,36^ A single low ROB study (n=345) found that intervention patients had an increased risk of ED readmission at 30 days.^40^ This was a multi-strategy intervention that included discharge planning and case management. It also included all 3 intervention components of interest. In a post hoc stratified analysis, this effect was seen only in patients who had not visited their primary care physician in the month prior to the ED index visit.

Another randomized study reported ED readmission, a primary outcome, as a continuous variable, measuring both number of hospitalizations and mean length of stay at 10 months’ follow-up.^39^ This study evaluated case management and included only 1 intervention component, assessment. There were no differences between the intervention and control groups.

Figure 5 Forest Plot of Effect of ED Interventions on Readmission^a^ a No summary estimate of effect is reported for nonrandomized studies because of the small number of studies and high ROB.

Abbreviations: CI=confidence interval; DC=discharge; ED=emergency department

Four nonrandomized studies reported ED readmission as a dichotomous variable.^44,45,47,48^ Three of these involved a single intervention strategy; discharge planning,^44^ case management,^48^ and medication management.^47^ One evaluated case management plus discharge planning.^45^ Two studies failed to find a difference in ED readmission rates between groups.^45,47^ One study included no intervention components of interest,^47^ while the other included assessment only.^45^ All participants admitted to the hospital in 1 study received the medication management intervention that had been provided only to the intervention group in the ED, decreasing the potential to observe an intervention effect.^47^ One study found that risk of ED readmission following an intervention was decreased (hazard ratio [HR] 0.49; 95% CI 0.33 to 0.72).^48^ Two intervention components, assessment and referral plus follow-up, were included in this study. However, the assessment was part of the standard of care in this study. In this study, a higher percentage of participants in the intervention group were discharged to home at the index ED visit and had a longer length of sustained contact with the geriatric team. It was shown that a majority of ED readmission occurred in the first week following the index ED visit. A majority of participants (73%) in the intervention group received a follow-up visit within the first 24 hours following the index ED visit. One study, whose only intervention component of interest was an assessment, found the risk of ED readmission to be increased (risk difference 3%, p=0.05) following receipt of the intervention.^44^ In this study, control case matches were low-risk participants while those in the intervention group were deemed to be high risk, meaning they had positively answered at least 1 of the 4 screening questions that gauge ability to care for self at home.

A final nonrandomized study reported ED readmission as a continuous outcome.^46^ This study evaluation discharge planning plus case management and included 1 intervention component of interest, referral plus follow-up. The number of visits to the ED within the 3 month follow-up period did not differ between groups.

### Quality of Evidence

Risk of bias is described for randomized studies in Figure 6. We separately evaluated objective outcomes (eg, mortality, ED readmission) and patient-reported outcomes (eg, QOL). For objective outcomes, 6 of the 9 studies were judged low or unclear ROB. Five studies were judged low or unclear ROB for patient-reported outcomes. Factors that led to higher ROB judgments included unclear randomization and allocation concealment, detection bias (patient-reported outcomes), and differences in baseline patient characteristics.

Figure 6 Risk of Bias Ratings for Randomized Studies^a^ a White indicates items that were not applicable. Green/positive indicates items that were judged low ROB. Yellow/question mark indicates items that were judged unclear ROB. Red/negative indicates items that were judged high ROB.

Nonrandomized studies (Figure 7) were judged high ROB for objective outcomes, with 1 exception that was judged low ROB.^48^ Because the EPOC quality criteria consider random sequence generation even for nonrandomized designs, this was a major factor in the high ROB ratings. Other concerns were lack of proof that baseline provider characteristics (eg, experience) were similar, and lack of proof that baseline outcome measurements were similar. Also, many studies had fundamental differences in baseline patient characteristics, which may affect outcomes.

Figure 7 Risk of Bias Ratings for Nonrandomized Studies^a^ a White indicates items that were not applicable. Green/positive indicates items that were judged low ROB. Yellow/question mark indicates items that were judged unclear ROB. Red/negative indicates items that were judged high ROB.