# Methods

We followed a standard protocol for this review. Each step was pilot-tested to train and calibrate study investigators. The PROSPERO registration number is CRD42018087660. We adhered to the Preferred Reporting Items for Systematic Reviews and Meta Analyses (PRISMA) guidelines, including the PRISMA Harms extension.^20^

## Topic Development

This topic was nominated by the VHA Offices of Geriatrics and Extended Care Operations and Emergency Medicine. The Key Question (KQ) and protocol, including the identification of intervention strategies and components, were developed a priori by the Durham Evidence-based Synthesis Program team in consultation with the operational partners and a technical expert panel. Topic development was informed by a search for recent systematic reviews, scoping reviews, or evidence maps. We rated the quality and retained those judged moderate^3,21–25^ or good^12–15^ to inform the final KQ and methods. We did not include studies that addressed the development of risk-assessment tools, as these have been reviewed recently and were not a priority for VHA.^22^

### Key Question

The KQ for this report was: How effective are emergency department (ED) interventions in improving clinical, patient experience, and utilization outcomes in older adults (age ≥65)?

### Emergency Department Intervention Strategies

For this review, ED interventions included the 4 major strategies described in Table 1. These strategies were identified before data abstraction and were based on prior reviews, existing literature, and consultation with our technical expert panel. We classified each study by its primary intervention strategy. Although 4 potentially distinct strategies are described, some studies evaluated multiple strategies (eg, discharge planning followed by case management, or case management that includes strategies for medication safety), and in these instances, we classified the intervention as “multi-strategy.”

Table 1 Emergency Department Intervention Strategies

Intervention Strategy | Definition
Discharge planning | Discharge planning is time-limited, taking place fully within the ED, and encompassing the process of thinking about and formalizing a plan of care prior to a patient’s discharge from the ED. Discharge planning may incorporate 1 or more of the following: geriatric consultation or geriatric assessment in the ED^a^, patient/caregiver education, or a follow-up plan. Although the initial assessment and discharge planning take place within the ED, the responsibility for coordinating and obtaining follow-up care rests with the patient or caregiver.
Case management | Case management takes place over time and across settings, initially beginning within the ED and continuing after discharge, and includes the activities that a physician or other health care professional performs to ensure coordination of medical services needed by the patient^b^. The ultimate goal of case management is to help support successful transition from the ED to post-ED settings. Unlike discharge planning, in which the patient or caregiver may be responsible for identifying and securing services, in case management the major responsibility and coordination rests with 1 or more providers.
Medication safety or management | Interventions that assist patients or caregivers in managing and monitoring drug therapy for older adults with chronic conditions^c^.
Geriatric EDs | EDs designed or guided by the 2014 Geriatric ED Guidelines.^16–18^

a The geriatric assessment is a multidimensional, multidisciplinary assessment designed to evaluate an older person’s functional ability, physical health, cognition and mental health, and socio-environmental circumstances. It must include a geriatrician or geriatric-trained nurse practitioner or physician assistant and may be a focused assessment that is customized for ED settings.

b We define case management narrowly to require a non-physician, either onsite in the ED or offsite, who is involved in coordinating follow-up care related to an ED visit. This may include home-based services.

c Interventions may incorporate a clinical pharmacist or other expert in drug therapy, or computerized interventions if they are conducted in real time (during patients’ ED admission). Interventions may be targeted to the clinician, patient, or family if they focus on the proper selection of medications, reduction in polypharmacy or medication errors, or use of medications. These interventions do not include shared decision-making approaches to choosing 1 treatment versus another.

Abbreviation: ED=emergency department

### Emergency Department Intervention Components

In addition to the major ED intervention strategies, we abstracted detailed information about the intervention structure. This included the timing and setting (eg, before ED discharge, after ED discharge, or both); target of intervention (eg, patient, caregiver/family member, provider); mode of delivery (eg, telephone, in-person); number and type of providers; number of planned contacts; and number of actual contacts. We also abstracted details about patient-focused intervention components (eg, assessment/screening, patient and/or caregiver education or support) and provider- or service-driven components (eg, referral to provider and/or community resources, follow-up call or visit, continuity of care/care coordination, environmental or procedural changes in response to 2014 Geriatric ED guidelines). An in-depth description of intervention strategies and components is in Appendix A.

Informed by prior literature,^26^ and using information from the detailed intervention abstractions, we hypothesized that 3 key intervention components would be associated with positive outcomes, as described in Table 2.

Table 2 Definitions of Key Emergency Department Intervention Components

Intervention Component | Definition
Assessment | A structured and/or targeted assessment performed as a part of the intervention. A structured assessment may include a comprehensive geriatric assessment or biopsychosocial assessment covering common domains including cognitive performance, functional status, social status and living environment, health behaviors, and psychosocial factors. Brief or targeted assessments may include 1 or more specific domains, such as cognitive performance or functional status.
Referral plus follow-up | Referral to 1 or more of the following: primary care provider, specialty provider, or community resource or services plus planned communication or visit(s) with intent of following up on referral.
Bridge | An intervention that takes place across settings, including 1 or more planned contacts before discharge from the ED and again after discharge.

Abbreviation: ED=emergency department

### Conceptual Framework

Conceptual frameworks are theory-driven and depict the hypothesized, or causal, relationships between behavioral determinants, intervention strategies, and key outcomes. Models also examine potential mediators and moderators of causal processes. In collaboration with our stakeholders and technical expert panel, and prior to the start of our review, we developed a conceptual framework (Figure 1) informed by existing research in geriatric emergency medicine. Existing literature suggests that, for older adults, the process of accessing and utilizing ED care results from an interaction between sociodemographic factors, clinical characteristics, personal preferences and prior experiences, and access to services.^27,28^ Although prior reviews have evaluated the effect of common ED interventions such as geriatric assessment and/or discharge planning, to our knowledge no reviews to date have mapped specific components of these interventions to a conceptual model, nor have any reviews examined interventions that use multiple strategies. In addition to evaluating the effect of the different ED intervention strategies described in the above, we collected additional details of the interventions. As depicted below, we grouped the intervention components into 2 main categories: (1) patient-focused intervention components (ie, intervention processes that gathered information from, or provided information to, the patient and/or caregiver) and (2) provider- or systems-focused components (ie, intervention processes that involve a provider, service, resource, or workflow in the larger healthcare system). Note that boxes shaded in gray depict constructs believed to influence initial need for ED care and modify the effect of the intervention. However, information depicted in these boxes was rarely included in the studies and was not abstracted or analyzed as a part of this report. Also not shown in the model are aspects of the intervention structure, described above (eg, setting, target, providers, number of planned contacts).

Figure 1 Conceptual Framework

Abbreviations: ED=emergency department; Geri=geriatric; HRQOL=health-related quality of life; PCMH=patient-centered medical home

## Search Strategy

In collaboration with an expert reference librarian, we employed a 2-stage search strategy, searching first for recent systematic reviews (SRs) or scoping reviews, and then conducting a search for primary literature not identified in these reviews. We searched MEDLINE^®^ (via PubMed^®^) and the Cochrane Library for high-quality SRs published from inception through October 17, 2017. We identified 7 relevant reviews, with the most recent being a high-quality scoping review whose search was conducted in Fall 2016.^7^ We searched MEDLINE (via PubMed), Embase, and CINAHL for primary literature published from January 1, 2016 through December 4, 2017. Overall, our approach was to utilize existing moderate- to high-quality SRs and scoping reviews to identify literature up to the most recent comprehensive search date, supplemented by a new literature search to the current date, and perform a de novo literature synthesis.

Our search strategy was informed by the Cochrane Effective Practice and Organization of Care (EPOC) Group.^29^ EPOC criteria were developed to capture both randomized and nonrandomized study designs. We used a combination of medical subject headings (MeSH), keywords, and selected free-text terms for the eligible interventions, geriatrics or older adults, and EDs (Appendix B). All citations were imported into 2 electronic databases (for referencing, EndNote^®^ Version X7, Thomson Reuters, Philadelphia, PA; for data abstraction, DistillerSR; Evidence Partners Inc., Manotick, ON, Canada).

## Study Selection

Using prespecified inclusion/exclusion criteria (Appendix C), 2 reviewers independently evaluated titles and abstracts to identify potentially eligible primary studies. Studies then advanced to the full-text review stage. To be eligible for inclusion at the full-text review stage, studies had to meet all eligibility criteria. Disagreements were resolved by consensus between the 2 investigators or by a third investigator. Articles meeting all eligibility criteria were included for data abstraction. Eligibility criteria included (1) older adults ≥65 of age presenting to the ED, (2) an eligible intervention (see Table 1), (3) a randomized or quasi-experimental study,^29^ and (4) conducted in an Organisation for Economic Cooperation and Development (OECD) country.

## Data Abstraction

Data from published reports were abstracted into a customized DistillerSR database by 1 reviewer and over-read by a second reviewer. Disagreements were resolved by consensus or by obtaining a third reviewer’s opinion when consensus was not reached. Key characteristics abstracted included patient descriptors, intervention characteristics, comparator, and outcomes. Multiple reports from a single study were treated as a single data point; we prioritized results based on the most complete and appropriately analyzed data. When critical data were missing or unclear in published reports, we requested supplemental data from the study authors. Key features relevant to applicability included the match between the sample and target populations (eg, age and Veteran status).

## Risk of Bias Assessment

Study risk of bias (ROB) was assessed independently by 2 investigators. Disagreements were resolved by consensus between the investigators or, when needed, by arbitration by a third investigator. We used the key ROB criteria described in the EPOC guidance.^29^ These criteria are adequacy of randomization and allocation concealment; comparability of groups at baseline; blinded outcomes assessment; completeness of follow-up and differential loss to follow-up; whether incomplete data were addressed appropriately; protection against contamination; and selective outcomes reporting (Appendix D). We assigned a summary ROB score (low, unclear, or high) separately to non-patient reported outcomes, hereafter referred to as objective outcomes (eg, mortality, ED readmission), and patient-reported outcomes (eg, quality of life).^29^ Summary ROB ratings were defined as follows:

- Low ROB: Bias, if present, is unlikely to alter the results seriously.
- Unclear ROB: A risk of bias that raises some doubts about the results.
- High ROB: Bias may alter the results seriously.

## Data Synthesis

We summarized the primary literature using relevant data abstracted from the eligible studies. Summary tables describe the key study characteristics of the primary studies: study design, patient demographics, and details of the intervention and comparator. We then determined the feasibility of completing a quantitative synthesis (ie, meta-analysis) to estimate summary effects. Feasibility depended on the volume of relevant literature, conceptual homogeneity of the studies, and completeness of results reporting. All analyses were stratified by randomized versus nonrandomized study designs.

We aggregated outcomes when there were at least 3 studies with the same outcome, reported at similar time points; for nonrandomized studies, we required adequately adjusted analyses to be reported. When quantitative synthesis was possible, dichotomous outcomes (ie, mortality, hospitalization after the ED visit, ED readmission) were combined using risk ratios random-effects. Continuous outcomes (eg, quality of life) were summarized using the mean difference. We used the Knapp Hartung approach to adjust the standard errors of the estimated coefficients in the random effects analyses.^30,31^ We evaluated statistical heterogeneity using visual inspection and Cochran’s Q and I^2^ statistics. We planned to assess publication bias using funnel plots but there were too few studies for these analyses to be meaningful. We planned subgroup analyses of moderator variables (eg, intervention strategy, intervention components), but there were too few studies to conduct these analyses.

When quantitative synthesis was not feasible, we analyzed the data qualitatively (ie, functional status, QOL, patient experience, hospitalization at the ED index visit). We gave more weight to the evidence from studies with a lower ROB and more precise estimates of effect. Qualitative synthesis focused on documenting and identifying patterns in efficacy and safety of the interventions across conditions and outcome categories. We analyzed potential reasons for inconsistency in treatment effects across studies by evaluating differences in the study population, intervention, comparator, and outcome definitions.

## Strength of the Body of Evidence

The strength of evidence (SOE) was assessed using the Grading of Recommendations Assessment, Development and Evaluation working group (GRADE) approach.^32^ In brief, this approach requires assessment of 4 domains: risk of bias, consistency, directness, and precision. These domains were considered qualitatively for the primary outcomes, and a summary rating of high, moderate, low, or very low SOE was assigned after evaluation in the GRADEpro software^33^ and discussion by 2 reviewers. SOE was assessed only for outcomes considered critical to decision making: functional status, ED readmission, hospital readmission, and patient experience.

## Peer Review

A draft version of this report was reviewed by technical experts and clinical leadership. A transcript of their comments and our responses is in Appendix E.