# Introduction

Older adults, especially those 75 years of age and over, have some of the highest rates of emergency department (ED) visits. In the United States, older adults make 64 ED visits per 100 persons annually, nearly twice the frequency of their younger counterparts.^1^ Within VA, older Veterans account for 40 percent of 2.4 million annual ED visits. This number will continue to rise, as the number of older Veterans is expected to increase significantly over the next decade.^2^

Older adults presenting to the ED can have a myriad of challenges that make care more difficult compared with younger adults. Such challenges include extensive medical histories with multiple morbidities, atypical symptoms or disease states, polypharmacy and adverse drug-drug interactions, and misunderstandings or misuse of prescription and over-the-counter medications.^3,4^ Additionally, older adults have different physiology compared with younger patients and may be challenged by functional disabilities, impaired cognition, communication problems, and reduced social support.^5,6^ These factors can make it difficult both for the older patient to navigate the hurried pace of the ED and for the health care provider to obtain a complete and accurate history, evaluate symptoms, make appropriate diagnoses, and optimize treatment.^3,7,8^ Any of these challenges can complicate assessment, diagnosis, treatment, and discharge, thereby negatively impacting care received while in the ED, transitions to home or other setting, and postdischarge health outcomes.^9,10^ In fact, older adults aged 75 and over are 3 times more likely to be admitted to the hospital from the ED.^1^

In addition to the factors noted above, optimal care for older adults visiting the ED may be difficult due to the physical space or design of the ED^11^ and decreased comfort of providers and staff in the care of older adults.^3^ However, individual and systems-level interventions may help address some of these challenges and improve both care processes and patient-related outcomes.

A broad range of interventions have been designed to improve clinical and utilization outcomes in older adult ED users. Broadly speaking, these interventions can be grouped into several categories including staffing, physical infrastructure, care delivery (including functional and geriatric assessments, and risk-prediction tools), case management, and transitional care or discharge planning.^7,12–15^

There has been growing attention to systems-level changes in geriatric emergency medicine practice and education, including the publication of the 2014 Geriatric Emergency Department Guidelines.^16–18^ These guidelines were a joint effort by the American College of Emergency Physicians, American Geriatrics Society, Emergency Nurses Association, and Society for Academic Emergency Medicine. These consensus guidelines offer a standard set of guidelines that are designed to be implemented in both general EDs and standalone geriatric EDs. More specifically, these guidelines provide a template for staffing, equipment, education, policies and procedures, follow-up care, and performance-improvement measures. They were the first multidisciplinary geriatric guidelines not aimed at addressing a specific condition or barrier, but rather addressing known challenges in caring for the elderly population at a systems level. The guidelines offer recommendations about important principles and processes in the care of older adults in the ED but do not recommend specific interventions or programs, acknowledging uncertainty in effectiveness. This gap highlights the need for a systematic review of ED intervention strategies.

The American College of Emergency Physicians (ACEP) has established an accreditation process for geriatric ED recognition. The standards to gain accreditation are meant to be applied across all settings, from rural to academic, within a regular ED or in a separate area. While there is not sufficient evidence that geriatric accreditation leads to improved clinical outcomes in ED settings, improved outcomes have been shown with accreditation for specific disease processes such as stroke.^19^

A 2017 scoping review to identify evidence addressing the identification and management of frail older people in the ED identified substantial literature and called for a careful synthesis to inform policy and clinical practice.^7^ Most prior studies of geriatric ED practices have focused on systems-level utilization outcomes, including length of stay, hospital admission, and repeat ED visits; few prior reviews have focused on patient-centered outcomes. Further, these reviews often classified interventions simply, potentially obscuring relationships between intervention components and outcomes, and no review has comprehensively evaluated a broad range of strategies. Our review aims to fill this gap by synthesizing evidence and including functional status and quality of life—2 clinical outcomes prioritized by VHA providers committed to preserving functional independence as critical to supporting older Veterans’ ability to age in place. Additionally, our review carefully classifies individual intervention components and uses rigorous analytic techniques to compare the effectiveness of selected interventions on outcomes of interest.

This review is intended to be used by the VHA Offices of Geriatrics and Extended Care Operations and Emergency Medicine to identify and evaluate intervention strategies in emergency care for older adults, with the goal of implementation across 141 VA EDs and urgent care centers. The review is also intended to provide guidance and establish priorities for an update of the Geriatric Emergency Medicine section of the ED Handbook to inform the future research agenda in VA geriatric emergency medicine.