# APPENDIX I Glossary

Term | Definition
Assessment | A structured and/or targeted assessment performed as a part of the intervention. A structured assessment may include a comprehensive geriatric assessment or biopsychosocial assessment covering common domains including cognitive performance, functional status, social status and living environment, health behaviors, and psychosocial factors. Brief or targeted assessments may include 1 or more specific domains, such as cognitive performance or functional status.
Bridge | An intervention that takes place across settings, including 1 or more planned contacts before discharge from the ED and again after discharge.
Case management | Case management takes place over time and across settings, initially beginning within the ED and continuing after discharge, and includes the activities that a physician or other health care professional performs to ensure coordination of medical services needed by the patient. The ultimate goal of case management is to help support successful transition from the ED to post-ED settings. Unlike discharge planning in which the patient or caregiver may be responsible for identifying and securing services, in case management, the major responsibility and coordination rests with 1 or more providers.
Discharge planning | Discharge planning is time-limited, taking place fully within the ED, and encompassing the process of thinking about and formalizing a plan of care prior to a patient’s discharge from the ED. Discharge planning may incorporate 1 or more of the following: geriatric consultation or geriatric assessment in the ED, patient/caregiver education, or a follow-up plan. Although the initial assessment and discharge planning take place within the ED, the responsibility for coordinating and obtaining follow-up care rests with the patient or caregiver.
Geriatric EDs | EDs designed or guided by the 2014 Geriatric ED Guidelines.^16–18^
Medication safety or management | Interventions that assist patients or caregivers in managing and monitoring drug therapy for older adults with chronic conditions.
Objective outcomes (ie, non–patient-reported outcomes) | Objective outcomes are measures that are not subject to a large degree of individual interpretation and are likely to be reliably measured across patients in a study, by different health care providers, and over time.^51^
Patient-reported outcomes | Patient-reported outcomes are directly reported by the patient without interpretation of the patient’s response by a clinician or anyone else and pertains to the patient’s health, quality of life, or functional status associated with health care or treatment.^52^
Referral plus follow-up | Referral to 1 or more of the following: primary care provider, specialty provider, or community resource or services plus planned communication or visit(s) with intent of following up on referral.
Risk of bias (ROB) | We used the key ROB criteria described in the Cochrane Effective Practice and Organization of Care (EPOC) guidance^29^:; - Randomization and allocation concealment; - Comparability of groups at baseline; - Blinded outcomes assessment; - Completeness of follow-up and differential loss to follow-up; - Whether incomplete data were addressed appropriately; - Protection against contamination; - Selective outcomes reporting.; Summary ROB ratings for a study:; - Low ROB—Bias, if present, is unlikely to alter the results seriously; - Unclear ROB—Bias that raises some doubts about the results; - High ROB—Bias that may alter the results seriously
Scoping review | Scoping reviews are used to identify knowledge gaps, set research agendas, and identify implications for decision-making. Scoping studies differ from systematic reviews because authors do not typically assess the quality of included studies.
Strength of evidence (SOE) | We assessed SOE using the Grading of Recommendations Assessment, Development and Evaluation (GRADE) approach for 4 domains^32^:
Strength of evidence (SOE) | Domain | Rating | How Assessed
Strength of evidence (SOE) | Risk of bias | Low; Unclear; High | Assessed primarily through study design and aggregate study quality
Strength of evidence (SOE) | Consistency | Consistent; Inconsistent; Unknown/NA | Assessed primarily through whether effect sizes are generally on the same side of “no effect,” the overall range of effect sizes, and statistical measures of heterogeneity
Strength of evidence (SOE) | Directness | Direct; Indirect | Assessed by whether the evidence involves direct comparisons or indirect comparisons through use of surrogate outcomes or use of separate bodies of evidence
Strength of evidence (SOE) | Precision | Precise; Imprecise | Based primarily on the size of the confidence intervals of effect estimates, the optimal information size and considerations of whether the confidence interval crossed the clinical decision threshold for using a therapy
Strength of evidence (SOE) | Summary SOE ratings for a body of evidence:; - High—High confidence that the true effect lies close to that of the estimate of the effect.; - Moderate—Moderate confidence in the effect estimate. The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.; - Low—Limited confidence in the effect estimate. The true effect may be substantially different from the estimate of the effect.; - Very low—Very little confidence in the effect estimate. The true effect is likely to be substantially different from the estimate of effect.; - Insufficient—Impossible or imprudent to rate. In these situations, a rating of insufficient is assigned.