# APPENDIX H Excluded Studies

Exclusion reason; Study | Not full publication | Not eligible country | Not population of interest | Not eligible setting | Not eligible intervention | Not eligible design | Not eligible outcome
Adedipe, 2006^1^ | | | | X
Aldeen, 2014^2^ | | | | | | X
Aldeen, 2014^3^ | X
Anonymous, 2010^4^ | X
Anonymous, 2011^5^ | X
Anonymous, 2012^6^ | X
Anonymous, 2012^7^ | X
Anonymous, 2013^8^ | X
Anonymous, 2014^9^ | X
Anonymous, 2015^10^ | X
Arendts, 2013^11^ | | | | | X
Arendts, 2017^12^ | | | | | X
Argento, 2010^13^ | X
Ballham, 2017^14^ | X
Bell, 2014^15^ | X
Brymer, 2001^16^ | | | | | X
Chou, 2015^17^ | X
Chui, 2013^18^ | X
Clegg, 2013^19^ | | | | X
Close, 1999^20^ | | | X
Conroy, 2014^21^ | | | X
Corbett, 2005^22^ | | | | | | X
Davison, 2005^23^ | | | X
deClifford, 2016^24^ | | | X
Edgren, 2016^25^ | | | X
Ellis, 2012^26^ | | | | | | X
Ellis, 2014^27^ | X
Fallon, 2015^28^ | | | | | | X
Foo, 2014^29^ | | X
Foo, 2012^30^ | | X
Fox, 2016^31^ | | | | | | X
Grudzen, 2015^32^ | | | | | | X
Gutteridge, 2014^33^ | | | | | X
Guttman, 2004^34^ | | | | | | X
Haag, 2016^35^ | | | | X
Harper, 2013^36^ | | | | | | X
Hegney, 2006^37^ | | | | | X
Hughes, 2014^38^ | X
Hullick, 2016^39^ | | | | X
Ismail, 2014^40^ | X
Jin, 2016^41^ | | | X
Jones, 2013^42^ | | | | | | X
Keelan, 2016^43^ | X
Keyes, 2014^44^ | | | | | | X
Knowles, 2016^45^ | | | X
Launay, 2013^46^ | | | | | | X
Launay, 2013^47^ | X
Launay, 2016^48^ | | | | X
Leah, 2010^49^ | | | | | | X
Leung, 2016^50^ | | X
Liao, 2012^51^ | | | | | | X
Mahony, 2008^52^ | | | | | X
Marsden, 2017^53^ | | | | | | | X
Moss, 2016^54^ | | | | | X
Ngian, 2008^55^ | | | | | | X
Nguyen, 2014^56^ | | | | | | X
Olufajo, 2016^57^ | | | | X
O’Reilly, 2016^58^ | X
Pareja, 2008^59^ | X
Pareja-Sierra, 2013^60^ | | | | | | X
Polinder, 2016^61^ | | | | | X
Rosenberg, 2016^62^ | | | | | | X
Sahota, 2017^63^ | | | | X
Salvi, 2008^64^ | | | | | | X
Santolaya-Perrin, 2016^65^ | | | | | | | X
Schubert, 2016^66^ | | | | X
Scott, 2014^67^ | X
Shaw, 2016^68^ | | | | | | X
Silvester, 2014^69^ | | | | | X
Sophia, 2014^70^ | X
Stergiopoulos, 2016^71^ | X
Tan, 2012^72^ | | | | | | X
Tang, 2016^73^ | X
Terrell, 2009^74^ | | | X
Waldron, 2011^75^ | | | | | X
Warburton, 2005^76^ | | | | | | X
Weir, 1999^77^ | | | | | | | X
Weng, 2017^78^ | | X
Wentworth, 2015^79^ | X
Wilber, 2013^80^ | X
Wright, 2014^81^ | | | | | | X
Yim, 2011^82^ | | | | | | | X
Yuen, 2013^83^ | | X

## References to Appendix H

1 Adedipe A, Lowenstein R. Infectious emergencies in the elderly. Emerg Med Clin North Am. 2006;24(2):433–448, viii.16584965
2 Aldeen AZ, Courtney DM, Lindquist LA, Dresden SM, Gravenor SJ. Geriatric emergency department innovations: preliminary data for the geriatric nurse liaison model. J Am Geriatr Soc. 2014;62(9):1781–1785.25112656
3 Aldeen AZ, Courtney DM, McCarthy DM, Dresden SM, Gravenor S. Geriatric-specific assessment intervention in the emergency department is associated with differences between initial and final disposition. Acad Emerg Med 2014;1):S233–S4. http://dx.doi.org/10.1111/acem.12365 2014.
4 Anonymous. Posters October, 1st. Eur Geriatr Med. 2010;1(Supplement 1):90–160.
5 Anonymous. Poster presentation clinical area. Eur Geriatr Med. 2011;2(Supplement 1):S24–S206.
6 Anonymous. IGS Abstracts 2012. Ir J Med Sci. 2012;181(7):191–299.
7 Anonymous. Abstracts. Age and Ageing. 2012;41(suppl_2):ii1–ii87.22820495
8 Anonymous. SAEM Annual Meeting Abstracts. Acad Emerg Med. 2013;20:S4–S336.23895627
9 Anonymous. SAEM Annual Meeting Abstracts. Acad Emerg Med. 2014;21:S5–S327.24787373
10 Anonymous. SAEM Annual Meeting Abstracts. Acad Emerg Med. 2015;22:S3–S425.25902946
11 Arendts G, Fitzhardinge S, Pronk K, Hutton M. Front-loading allied health intervention in the emergency department does not reduce length of stay for admitted older patients. Int J Clin Pract. 2013;67(8):807–810.23869682
12 Arendts G, Love J, Nagree Y, Bruce D, Hare M, Dey I. Rates of Delirium Diagnosis Do Not Improve with Emergency Risk Screening: Results of the Emergency Department Delirium Initiative Trial. J Am Geriatr Soc. 2017;65(8):1810–1815.28675451
13 Argento V, Grey W, Donal Conway JF, Skudlarska B. Experiences from a geriatric emergency room: The first 100 cases. Eur Geriatr Med 2010;1:S1072010.
14 Ballham S, Buxton S, Camacho R, Sinclair A, Dyer C, Jakeman N. 36 Frailty flying squad: an emergency department focussed acute care of the elderly service DR genevieve robson, royal united hospital NHS foundation trust. Emerg Med J. 2017;34(12):A885–a886.
15 Bell C, Hashemi N, Wieland F, Lowrey C, Kaur V. ACE impact: Evaluation of an integrated geriatric service. Age Ageing 2014;43:ii72014.
16 Brymer C, Cavanagh P, Denomy E, Wells K, Cook C. The effect of a geriatric education program on emergency nurses. J Emerg Nurs. 2001;27(1):27–32.11174267
17 Chou MY, Chou SL, Liang CK, Liao MC, Hsueh KC, Lin YT, . The effectiveness of comprehensive geriatric assessment-based intervention reducing frequent emergency department visits in a tertiary medical center in Southern Taiwan. Eur Geriatr Med 2015;6:S332015.
18 Chui CPY, Kun E. Geriatric consultation service in emergency department. Eur Geriatr Med. 2013;4(Supplement 1):S136.
19 Clegg A, Young J, Iliffe S, Rikkert MO, Rockwood K. Frailty in elderly people. Lancet. 2013;381(9868):752–762.23395245
20 Close J, Ellis M, Hooper R, Glucksman E, Jackson S, Swift C. Prevention of falls in the elderly trial (PROFET): a randomised controlled trial. Lancet. 1999;353(9147):93–97.10023893
21 Conroy SP, Ansari K, Williams M, . A controlled evaluation of comprehensive geriatric assessment in the emergency department: the ‘Emergency Frailty Unit’. Age Ageing. 2014;43(1):109–114.23880143
22 Corbett HM, Lim WK, Davis SJ, Elkins AM. Care coordination in the Emergency Department: improving outcomes for older patients. Aust Health Rev. 2005;29(1):43–50.15683355
23 Davison J, Bond J, Dawson P, Steen IN, Kenny RA. Patients with recurrent falls attending Accident & Emergency benefit from multifactorial intervention--a randomised controlled trial. Age Ageing. 2005;34(2):162–168.15716246
24 deClifford JM, Caplygin FM, Lam SS, Leung BK. Impact of an emergency department pharmacist on prescribing errors in an Australian hospital. J Pharm Pract Res. 2016;46:25–27.
25 Edgren G, Anderson J, Dolk A, . A case management intervention targeted to reduce healthcare consumption for frequent Emergency Department visitors: results from an adaptive randomized trial. Eur J Emerg Med. 2016;23(5):344–350.25969342
26 Ellis G, Jamieson CA, Alcorn M, Devlin V. An Acute Care for Elders (ACE) unit in the emergency department. Eur Geriatr Med. 2012;3(4):261–263.
27 Ellis G. Timely care for frail older people: the next battleground. Age and Ageing. 2014;43(5):732–732.
28 Fallon A, Armstrong J, Coughlan T, Collins DR, O’Neill D, Kennelly SP. Characteristics and Outcomes of Older Patients Attending an Acute Medical Assessment Unit. Ir Med J. 2015;108(7):210–211.26349351
29 Foo CL, Siu VW, Ang H, Phuah MW, Ooi CK. Risk stratification and rapid geriatric screening in an emergency department - a quasi-randomised controlled trial. BMC Geriatr. 2014;14:98.25178312
30 Foo CL, Siu VW, Tan TL, Ding YY, Seow E. Geriatric assessment and intervention in an emergency department observation unit reduced re-attendance and hospitalisation rates. Australas J Ageing. 2012;31(1):40–46.22417153
31 Fox J, Pattison T, Wallace J, . Geriatricians at the front door: The value of early comprehensive geriatric assessment in the emergency department. Eur Geriatr Med. 2016;7(4):383–385.
32 Grudzen C, Richardson LD, Baumlin KM, . Redesigned geriatric emergency care may have helped reduce admissions of older adults to intensive care units. Health Aff (Millwood). 2015;34(5):788–795.25941280
33 Gutteridge DL, Genes N, Hwang U, Kaplan B, Investigators GW, Shapiro JS. Enhancing a geriatric emergency department care coordination intervention using automated health information exchange-based clinical event notifications. EGEMS (Wash DC). 2014;2(3):1095.25848622
34 Guttman A, Afilalo M, Guttman R, . An emergency department-based nurse discharge coordinator for elder patients: does it make a difference? Acad Emerg Med. 2004;11(12):1318–1327.15576523
35 Haag JD, Davis AZ, Hoel RW, . Impact of pharmacist-provided medication therapy management on healthcare quality and utilization in recently discharged elderly patients. Am Health Drug Benefits. 2016;9(5):259–267.27625743
36 Harper KJ, Gibson NP, Barton AD, Petta AC, Pearson SK, Celenza A. Effects of emergency department Care Coordination Team referrals in older people presenting with a fall. Emerg Med Australas. 2013;25(4):324–333.23911023
37 Hegney D, Buikstra E, Chamberlain C, . Nurse discharge planning in the emergency department: a Toowoomba, Australia, study. J Clin Nurs. 2006;15(8):1033–1044.16879548
38 Hughes CT, Laghi L, Wyrko Z. Experience of the ‘Older Persons Assessment and Liaison (OPAL)’ service in a teaching hospital in Birmingham, UK. Eur Geriatr Med 2014;5:S248. 2014.
39 Hullick C, Conway J, Higgins I, . Emergency department transfers and hospital admissions from residential aged care facilities: a controlled pre-post design study. BMC Geriatr. 2016;16:102.27175921
40 Ismail S, Fox G, Cracknell A, Burns E. Interface Geriatrics and new ways of working: Avoiding admissions by implementing early specialist assessment by interface geriatricians in the Emergency Department (ED). Age Ageing 2014;43:i142014.
41 Jin B, Zhao Y, Hao S, . Prospective stratification of patients at risk for emergency department revisit: Resource utilization and population management strategy implications. BMC Emergency Medicine. 2016;16(1).
42 Jones S, Wallis P. Effectiveness of a geriatrician in the emergency department in facilitating safe admission prevention of older patients. Clin Med (Lond). 2013;13(6):561–564.24298101
43 Keelan R, Briggs S, Wentworth L. Comprehensive geriatric assessment in emergency Department by OPAL (Older People Assessment and Liaison) can prevent admissions. Future Healthcare Journal. 2016. Available at: http://futurehospital.rcpjournal.org/content/3/Suppl_2/s26.short. Accessed June 21, 2018.
44 Keyes DC, Singal B, Kropf CW, Fisk A. Impact of a new senior emergency department on emergency department recidivism, rate of hospital admission, and hospital length of stay. Ann Emerg Med. 2014;63(5):517–524.24342817
45 Knowles E, O’Cathain A, Turner J, Nicholl J. Effect of a national urgent care telephone triage service on population perceptions of urgent care provision: Controlled before and after study. BMJ Open. 2016;6(10).
46 Launay C, Annweiler C, de Decker L, Kabeshova A, Beauchet O. Early hospital discharge of older adults admitted to the emergency department: effect of different types of recommendations made by a mobile geriatric team. J Am Geriatr Soc. 2013;61(6):1031–1033.23772731
47 Launay C, de Decker L, Annweiler C, Beauchet O. Early hospital discharge of older adults admitted to emergency department: Effect of the different types of recommendations made by a mobile geriatric team. Eur Geriatr Med. 2013;4(Supplement 1):S71.
48 Launay CP, de Decker L, Kabeshova A, Annweiler C, Beauchet O. Risk of Unplanned Emergency Department Readmission after an Acute-Care Hospital Discharge among Geriatric Inpatients: Results from the Geriatric EDEN Cohort Study. J Nutr Health Aging. 2016;20(2):210–217.26812519
49 Leah V, Adams J. Assessment of older adults in the emergency department. Nurs Stand. 2010;24(46):42–45.
50 Leung SC, Leung LP, Fan KL, Yip WL. Can prehospital Modified Early Warning Score identify non-trauma patients requiring life-saving intervention in the emergency department? Emerg Med Australas. 2016;28(1):84–89.26608099
51 Liao M-C, Chen L-K, Chou M-Y, . Effectiveness of Comprehensive Geriatric Assessment-Based Intervention to Reduce Frequent Emergency Department Visits: A Report of Four Cases. International Journal of Gerontology. 2012;6(2):131–133.
52 Mahony SO, Blank A, Simpson J, . Preliminary report of a palliative care and case management project in an emergency department for chronically ill elderly patients. J Urban Health. 2008;85(3):443–451.18363108
53 Marsden E, Taylor A, Wallis M, . A structure, process and outcome evaluation of the Geriatric Emergency Department Intervention model of care: a study protocol. BMC Geriatr. 2017;17(1):76.28330452
54 Moss JM, Bryan WE, Wilkerson LM, . Impact of clinical pharmacy specialists on the design and implementation of a quality improvement initiative to decrease inappropriate medications in a veterans affairs emergency department. J Manag Care Spec Pharm. 2016;22(1):74–80.27015054
55 Ngian VJ, Ong BS, O’Rourke F, Nguyen HV, Chan DK. Review of a rapid geriatric medical assessment model based in emergency department. Age Ageing. 2008;37(6):696–699.18703521
56 Nguyen A, Straney L, Cameron P, Lowthian J. Synthesised geriatric assessment in the Emergency Department setting: is it NEAT? Aust Health Rev. 2014;38(4):370–376.25055343
57 Olufajo OA, Tulebaev S, Javedan H, . Integrating Geriatric Consults into Routine Care of Older Trauma Patients: One-Year Experience of a Level I Trauma Center. J Am Coll Surg. 2016;222(6):1029–1035.26968324
58 O’Reilly C, Maloney P, Alexander E, . 230 Frail intervention therapy team: a step in the right direction. early assessment in the emergency department. Age and Ageing. 2016;45(suppl_2):ii13–ii56.
59 Pareja T. Do geriatric interventions in the Emergency Department reduce the need of Hospital admission of frail older adults? J Am Geriatr Soc 2008;56:S126–S72008.
60 Pareja-Sierra T, Hornillos-Calvo M, Rodriguez-Solis J, . Implementation of an emergency department observation unit for elderly adults in a university-affiliated hospital in Spain: a 6-year analysis of data. J Am Geriatr Soc. 2013;61(9):1621–1622.24028361
61 Polinder S, Boye ND, Mattace-Raso FU, . Cost-utility of medication withdrawal in older fallers: results from the improving medication prescribing to reduce risk of FALLs (IMPROveFALL) trial. BMC Geriatr. 2016;16(1):179.27809792
62 Rosenberg M, Rosenberg L. The Geriatric Emergency Department. Emerg Med Clin North Am. 2016;34(3):629–648.27475018
63 Sahota O, Pulikottil-Jacob R, Marshall F, . The Community In-reach Rehabilitation and Care Transition (CIRACT) clinical and cost-effectiveness randomisation controlled trial in older people admitted to hospital as an acute medical emergency. Age and Ageing. 2017;46(1):26–32.28180236
64 Salvi F, Morichi V, Grilli A, . A geriatric emergency service for acutely ill elderly patients: pattern of use and comparison with a conventional emergency department in Italy. J Am Geriatr Soc. 2008;56(11):2131–2138.19016945
65 Santolaya-Perrín R, Jiménez-Díaz G, Galán-Ramos N, . A randomised controlled trial on the efficacy of a multidisciplinary health care team on morbidity and mortality of elderly patients attending the Emergency Department. Study design and preliminary results. Farmacia Hospitalaria. 2016;40(5):371–384.27570988
66 Schubert CC, Myers LJ, Allen K, Counsell SR. Implementing Geriatric Resources for Assessment and Care of Elders Team Care in a Veterans Affairs Medical Center: Lessons Learned and Effects Observed. J Am Geriatr Soc. 2016;64(7):1503–1509.27305428
67 Scott S, Bertram RE, Andrew A, Ray R. Comprehensive geriatric assessment (CGA) in the Emergency Department by OPAL (Older People Assessment and Liaison): Does it prevent admissions? Eur Geriatr Med 2014;5:S2492014.
68 Shaw PB, Delate T, Lyman A, Jr., . Impact of a Clinical Pharmacy Specialist in an Emergency Department for Seniors. Ann Emerg Med. 2016;67(2):177–188.26211427
69 Silvester KM, Mohammed MA, Harriman P, Girolami A, Downes TW. Timely care for frail older people referred to hospital improves efficiency and reduces mortality without the need for extra resources. Age Ageing. 2014;43(4):472–477.24222658
70 Sophia R, Bashir WA. A geriatrician in the emergency department. GM J. 2014; 44: 32–34.
71 Stergiopoulos V, Gozdzik A, Tan de Bibiana J, . Brief case management versus usual care for frequent users of emergency departments: the Coordinated Access to Care from Hospital Emergency Departments (CATCH-ED) randomized controlled trial. BMC Health Serv Res. 2016;16(1):432.27557705
72 Tan KM, Lannon R, O’Keeffe L, . Geriatric medicine in the emergency department. Ir Med J. 2012;105(8):271–274.23155914
73 Tang K, Lavery P, Maybin C, Amir K. 198 Developing a rapid access unit (RAC) to improve quality of care for elderly patients attending the local emergency department. Age Ageing 2016;45:402016.
74 Terrell KM, Perkins AJ, Dexter PR, Hui SL, Callahan CM, Miller DK. Computerized decision support to reduce potentially inappropriate prescribing to older emergency department patients: a randomized, controlled trial. J Am Geriatr Soc. 2009;57(8):1388–1394.19549022
75 Waldron N, Dey I, Nagree Y, Xiao J, Flicker L. A multi-faceted intervention to implement guideline care and improve quality of care for older people who present to the emergency department with falls. BMC Geriatr. 2011;11:6.21281473
76 Warburton RN. Preliminary outcomes and cost-benefit analysis of a community hospital emergency department screening and referral program for patients aged 75 or more. Int J Health Care Qual Assur Inc Leadersh Health Serv. 2005;18(6–7):474–484.16335613
77 Weir R, Browne G, Byrne C, . The quick response initiative in the emergency department: who benefits? Health Care Manag Sci. 1999;2(3):137–148.10934538
78 Weng SC, Chen YC, Chen CY, . Application of qualitative response models in a relevance study of older adults’ health depreciation and medical care demand. Geriatr Gerontol Int. 2017;17(4):645–652.27246701
79 Wentworth L, Briggs S, Keelan R, Ashraf S, Wileman L, Williams J. A comprehensive geriatric assessment in the emergency department reduces admissions and length of stay. Eur Geriatr Med 2015;6:S22–S32015.
80 Wilber ST, Blake K, Bosley D, Cleveland ML, Cox SR, Holder C, . Outcomes of a Pilot Senior Emergency Department Program. Ann Emerg Med 2013;62:S532013.
81 Wright PN, Tan G, Iliffe S, Lee D. The impact of a new emergency admission avoidance system for older people on length of stay and same-day discharges. Age Ageing. 2014;43(1):116–121.23907007
82 Yim VW, Rainer TH, Graham CA, . Emergency department intervention for high-risk elders: identification strategy and randomised controlled trial to reduce hospitalisation and institutionalisation. Hong Kong Med J. 2011;17(3 Suppl 3):4–7.
83 Yuen TM, Lee LL, Or IL, . Geriatric consultation service in emergency department: how does it work? Emerg Med J. 2013;30(3):180–185.22447816