# APPENDIX G Intervention Characteristics Tables

For full study citations in this appendix, please refer to the report’s main reference list.

## Randomized Studies

Study | Intervention Setting/Timing; Intervention Target | # of Providers; Type of Provider(s); Geriatrics Trained? | Patient-focused Intervention Components^a^ | Provider- or Systemfocused Intervention Components^a^ | Mode of Delivery; # Planned Contacts
Single-Strategy Interventions
Case Management/Transition of Care
Basic, 2005^34^ | Pre-ED discharge; Patient | Single provider; RN; Yes | - Comprehensive assessment; - Caregiver support; - No medication review or rehabilitation intervention; - No intervention | - Referral to specialists; - Communication between providers; - No follow-up | In-person; 1
Caplan, 2004^37^ | Before and after ED discharge (Bridge)^b^; Patient | Multiple providers; MD, RN, PT; Yes | - Semi-structured assessment of function & cognition; - No education/support; - No medication review or rehabilitation intervention | - Follow-up communication; - Referrals to specialists, community services; - Interdisciplinary team meeting | In-person; 1
Gagnon, 1999^39^ | Post-ED; Patient | Single provider; RN; Yes | - Comprehensive assessment; - No education/support; - No medication review or rehabilitation intervention | - Follow-up visit scheduled; - Interdisciplinary team meeting; - No referrals to specialist | In-person; NR
Runciman, 1996^42^ | Post-ED; Patient | Multiple providers; PT; NR | - Comprehensive in-home assessment; - No education/support; - No medication review or rehabilitation intervention | - Referrals to community services; - No follow-up; - No continuity of care | In-person; NR
Multi-Strategy Interventions
Discharge Planning PLUS Case Management/Transition of Care
Eklund, 2013^38^ | Before and after ED discharge (Bridge)^b^; Patient | Multiple providers; RN; Yes | - Frailty screening & geriatric assessment; - No education/support; - No medication review or rehabilitation intervention | - Follow-up visit scheduled; - Interdisciplinary team meeting; - No referrals | In-person, telephone; NR
McCusker, 2001^40^ | Before and after ED discharge (Bridge)^b^; Patient | Multiple providers; MD, RN, SW; Yes | - Brief standardized geriatric nursing assessment; - No education/support; - No medication review or rehabilitation intervention | - Follow-up communication; - Referral to primary care provider, specialists; - No continuity of care | In-person, telephone; NR
Mion, 2003^41^ | Before and after ED discharge (Bridge)^b^; Patient, caregiver | Multiple providers; RN, SW; Yes | - Comprehensive geriatric assessment; - Caregiver support; - No medication review or rehabilitation intervention | - Follow-up communication; - Referrals to community services; - Communication between providers | In-person, telephone; NR
Case Management/Transition of Care PLUS Medication Management
Biese, 2014^35^ | Post-ED; Patient | Single provider; RN; NR | - Medication review; - No assessment/screening; - No education/support; - No rehabilitation intervention | - Follow-up visits scheduled; - Referrals to community services; - No continuity of care | Telephone; NR
Biese, 2017^36^ | Post-ED; Patient | Single provider; RN; NR | - Medication review; - No assessment screening; - No education/support; - No rehabilitation intervention | - Referrals to community services; - No follow-up; - No continuity of care | Telephone; 1

a Bolded text indicates intervention components that were present in the study. Italicized text indicates intervention components were not present in the study.

b Bridge setting refers to interventions conducted both before ED discharge and after ED discharge.

Patient-focused intervention components include comprehensive assessment and/or risk screening, patient and/or caregiver education and/or support, intervention (medication, rehabilitation). See Appendix A for more detail.

Provider or systems-focused intervention components include planned follow-up communication or visit, referral to provider, specialist or community resource, continuity of care/care coordination, and changes to ED environment and/or procedures. See Appendix A for more detail.

Abbreviations: ED=emergency department; NR=not reported; MD=physician; RN=nurse; SW=social worker; PT=physical therapist; OT=occupational therapist.

## Nonrandomized Studies

Study | Setting Intervention Target | # of Providers; Type of Provider(s); Geriatrics Trained? | Patient-focused Intervention Components^a^ | Provider- or System-directed Intervention Components^a^ | Mode; # Planned Contacts
Single-Strategy Interventions
Discharge Planning
Arendts, 2012^43^ | Pre-ED discharge; Patient | Multiple providers; SW, PT; Yes | - Comprehensive functional assessment; - No education/support; - No medication review or rehabilitation intervention | - Interdisciplinary team meeting; - No follow-up; - No referral | In-person; 1
Arendts, 2013^44^ | Pre-ED; Patient | Multiple providers; MD, RN, SW, PT; Yes | - High-risk screening; comprehensive functional & needs assessment; - No education/support; - No medication review or rehabilitation intervention | - Referrals made (no details provided); - No follow-up; - No continuity of care | In-person; 1
Case Management/Transition of Care
Pedersen, 2016^48^ | Post-ED; Patient | Multiple providers; MD, RN; Yes | - Assessment part of routine ED care; - No education/support; - No medication review or rehabilitation intervention | - Home visit scheduled; - Patient-initiated follow-up communication; - Referrals to primary care provider, community services; - No continuity of care | In-person; 1
Medication Management
Mortimer, 2011^47^ | Pre-ED discharge; Patient | Single providers; NR; Yes | - Patient education; - Medication review & reconciliation; - No assessment/screening; - No rehabilitation intervention | - Referrals to other health services; - No follow-up; - No continuity of care | In-person; NR
Multi-Strategy Interventions
Discharge Planning PLUS Case Management/Transition of Care
Bond, 2014^45^ | Pre-ED discharge; Patient, caregiver | Single provider; RN; Yes | - Assessment performed by ED care coordinator; - Caregiver education & support; - No medication review or rehabilitation intervention | - Referral to community services; - No follow-up; - No continuity of care | In-person; NR
Miller, 1996^46^ | Before and after ED discharge (Bridge)^b^; Patient | Multiple providers; MD, RN; Yes | - Caregiver support; - No assessment/screening; - No medication review or rehabilitation intervention | - Follow-up communication/visit; - Referral to provider, community services; - Interdisciplinary team meeting | In-person; 1

a Bolded text indicates intervention components that were present in the study. Italicized text indicates intervention components not present in the study.

b Bridge setting refers to interventions conducted both before ED discharge and after ED discharge.

Patient-focused intervention elements include comprehensive assessment and/or risk screening, patient and/or caregiver education and/or support, intervention (medication, rehabilitation). See Appendix A for more detail.

Provider or systems-focused intervention elements include planned follow-up communication or visit, referral to provider, specialist or community resource, continuity of care/care coordination, and changes to ED environment and/or procedures. See Appendix A for more detail.

Abbreviations: ED=emergency department; NR=not reported; MD=physician; RN=nurse; SW=social worker; PT=physical therapist; OT=occupational therapist.