# APPENDIX F Study Characteristics Tables

For full study citations in this appendix, please refer to the report’s main reference list.

## Randomized Studies

Study; Country; # Enrolled; # of Arms | Key Intervention Components | Eligibility | Population High Risk?; Mean Age (SD); Female %; Race %; Living Alone %; Top 3 Conditions | Outcomes Reported^a^; Outcome Timing; Primary Outcome | Risk of Bias for Objective and Patient-Reported Outcomes^b^
Single-Strategy Interventions
Case Management/Transition of Care
Basic, 2005^34^; Australia; 224; 2 | Comprehensive assessment; Referral to specialist, no follow-up; Intervention delivered within ED | Inclusion: “Older adult” functional impairment; psychological disability; social disability; active multisystem disease; Exclusion^c^: Medically unstable; living in nursing home | High risk: Yes, based on functional status or other; Age: 78.7 (6.4); Female: 60%; Race: NR; Living alone: 39%; Top 3: Musculoskeletal, cardiovascular, neurological | Functional status: Modified; Barthel index; Hospitalization: At index^d^ visit; Timing: Index visit; Primary: Index hospital admission, length of inpatient stay, functional decline | Objective: High; Patient: High
Caplan, 2004^37^; Australia; 739; 2 | Semi-structured assessment; Referral plus follow-up; Intervention delivered both within and after discharge from ED (“bridge”) | Inclusion: Aged ≥75; Exclusion: Lived in a nursing home; previously enrolled in this study | High risk: No; Age: 82.2 (6.0); Female: 61%; Race: NR; Living alone: 39%; Top 3: Ischemic heart disease, falls, diabetes mellitus | Functional status: Composite; Mortality; Hospitalization: After index visit; ED readmit; Timing: 30 days; 3, 6, 12, 18 months; Primary: All hospital admissions within 30 days of ED visit | Objective: Low; Patient: Unclear
Gagnon, 1999^39^; Canada; 427; 2 | Comprehensive Assessment; No referral, only follow-up; Intervention delivered only after discharge from ED | Inclusion: Aged ≥70 with cardiac disease (part of risk assessment); Exclusion: Admitted to ED from long-term care facility or nursing home; currently in another research study or followed by a geriatric team; hospitalized; partner already enrolled | High risk: Yes, based on ADL and Boult assessment tool; Age: 81.6 (6.4) Female: 58%; Race: NR; Living alone: 61%; Top 3: Diabetes, cardiac | Functional Status: ADL, IADL; Quality of life: SF-36; Mortality; Patient experience; Hospitalization: follow-up; ED readmit; Timing: 10 months; Primary: Quality of life, satisfaction with care, functional status, admission to hospital, length of hospital stay, or readmission to ED | Objective: Unclear; Patient: Unclear
Runciman, 1996^42^; Europe; 424; 2 | Comprehensive assessment; No referral or follow-up; Intervention delivered only after discharge from ED | Inclusion: Aged ≥75; accident; Exclusion: NR | High risk: No; Age: 81 (NR); Female: NR; Race: NR; Living alone: NR; Top 3: Fall and soft-tissue injury | Functional Status: SF-36; Patient experience: Informal; ED readmit; Timing: 4 weeks; Primary: Patient satisfaction, ED readmission rate, dependency, functional outcome | Objective: Unclear; Patient: Unclear
Multi-Strategy Interventions
Discharge Planning PLUS Case Management/Transition of Care
Eklund, 2013^38^; Europe; 181; 2 | Geriatric assessment; Referral plus follow-up; Intervention delivered both within and after discharge from ED (“bridge”) | Inclusion: Aged 65-79 with 1 or more chronic disease and dependent in 1 or more ADLs, or ≥ age 80; Exclusion: Dementia; palliative care; and acute severe illness with immediate need of assessment and treatment by physician | High risk: Yes, based on ADL and diagnosis; Age: NR; Female: 55%; Race: NR; Living alone: NR; Top 3: Frail, visual impairment | Functional status; Timing: 3, 6, 9, 12 months; Primary: Frailty (Berg Balance scale) | Objective: NA; Patient: High
McCusker, 2001^40^; Canada; 388; 2 | Brief nursing assessment; Referral plus follow-up; Intervention delivered both within and after discharge from ED (“bridge”) | Inclusion: Aged ≥65; Exclusion: Referred from nursing home or chronic disease hospital; patient expected by ED staff to be admitted; medically unstable or cognitively impaired with no family as proxy; already seen by a member of the hospital’s geriatric staff prior to enrollment | High risk: Yes, based on ISAR score; Age: 76.6 (7.0); Female: 61%; Race: NR; Living alone: 40%; Top 3: Cardiorespiratory, musculoskeletal, digestive | Functional status: ADL; Patient experience; Hospitalization: At index visit; ED readmit; Costs; Timing: 1, 4 months; Primary: functional status and depression, change in caregiver physical and mental health status, patient and caregiver satisfaction with care | Objective: Low; Patient: Low
Mion, 2003^41^; USA; 650; 2 | Comprehensive assessment; Referral plus follow-up; Intervention delivered both within and after discharge from ED (“bridge”) | Inclusion: Aged ≥65; Exclusion: Not expected to discharge from ED; impaired hearing; no family caregiver as proxy for cognitively impaired | High risk: No; Age: 74.4 (6.9); Female: 59%; Race: White (39%), other categories (NR); Living alone: NR; Top 3: NR | Functional status: SF36; Mortality; Patient experience; Hospitalization: After index visit; ED readmit; Costs; Timing: 30, 120 days; Primary: Health care service use (defined as ED, hospital, nursing home, health care costs) | Objective: Low; Patient: Low
Case Management/Transition of Care PLUS Medication Management
Biese, 2014^35^; USA; 178; 3 | No assessment; Referral to community services plus follow-up; Intervention delivered after discharge from ED | Inclusion: Aged ≥65; Exclusion: Admitted to hospital; discharged to setting other than home; not referred to outpatient follow-up; cognitively impaired; patient excluded from primary outcome ONLY if returned to ED or was hospitalized within 5 days of index ED visit | High risk: No; Age: 75 (7.58); Female: 60%; Race: White (67%-74%), Black (23%-31%); Living alone: NR; Top 3: NR | Hospitalization: After index visit; ED readmit; Costs; Timing: 35 days; Primary: Post-ED discharge measured by expedited outpatient follow-up and/or increased compliance with medication changes | Objective: High; Patient: High
Biese, 2017^36^; USA; 2000; 2 | No assessment; Referral, no follow-up; Intervention delivered post ED discharge | Inclusion: Aged ≥65; Exclusion: discharged to hospice or skilled care facility or correctional institution; failed cognitive test; no phone; no ER note; psychiatric reason for ER visit; left ER against medical advice prior enrollment or refusal | High risk: No; Age: 74 (7.1); Female: 60%; Race: White (77%), Black (19%); Living alone: NR; Top 3: Traumatic injury, pain (any), cardiac symptoms | Mortality; Hospitalization: After index visit; ED readmit; Timing: 30 days; Primary: Composite of # days from ED discharge to return to ED, hospitalization, or death | Objective: Unclear; Patient: High

a Outcomes limited to those prioritized for this review.

b Objective outcomes (ie, non–patient-reported outcomes): mortality, hospitalization, ED readmission. Patient-reported outcomes; health-related quality of life, functional status, patient experience.

c Exclusion criteria shown are limited to those relevant to this review.

d Index refers to the ED visit during which study enrolment occurred.

Abbreviations: ADL=activities of daily living; ED=emergency department; IADL=independent activities of daily living; ISAR=identification of seniors at risk; NA=not applicable; NR=not reported; SD=standard deviation; SF-36=short-form health assessment questionnaire

## Nonrandomized Studies

Study; Country; # Enrolled; # of Arms | Key Intervention Components | Eligibility | Population High Risk?; Mean Age (SD); Female %; Race %; Living Alone %; Top 3 Conditions | Outcomes Reported^a^; Outcome Timing; Primary Outcome | Risk of Bias for Objective and Patient-Reported Outcomes^b^
Single-Strategy Interventions
Discharge Planning
Arendts, 2012^43^; Australia; 5265; 2 | Comprehensive assessment; No referral or follow-up; Intervention delivered within ED | Inclusion: Aged ≥65;10 conditions including UTI, respiratory infection, fall with minor injury, hip or knee pain, back pain, cardiac failure, angina pectoris, syncope, TIA, new onset confusion or delirium; Exclusion^c^: Need for immediate resuscitation; triage to critical care bay in ED or other urgent medical input needed | High risk: Yes, diagnosis; Age: 79.6 (8.0); Female: 55%; Race: NR; Living alone: 30%; Top 3: Angina, cardiac failure, respiratory infection | Hospitalization: At index^d^ visit; Timing: At index visit; Primary outcome: Proportion of hospital admissions from ED | Objective: High; Patient: NA
Arendts, 2013^44^; Australia; 2196; 2 | Comprehensive assessment (only high-risk group); Referrals only, no follow-up; Intervention delivered within ED | Inclusion: Aged ≥65; Exclusion: cognitively impaired without surrogate; ED arrival and discharge between 21:00 and 7:00 | High risk: Yes, admitted; Age: 77.5 (8.0); Female: 56%; Race: NR; Living alone: 31%; Top 3: Fall (no injury or minor injury), ischemic chest pain, non-traumatic musculoskeletal pain | Mortality; Hospitalization: After index visit; ED readmission; Timing: 28 days; Primary outcome: ED visit within 28 days | Objective: High; Patient: NA
Case Management/Transition of Care
Pedersen, 2016^48^; Europe; 1330; 2 | Assessment part of routine care; Referral plus follow-up; Intervention delivered after discharge from ED | Inclusion: Aged ≥70; pneumonia, COPD, delirium, dehydration, UTI, constipation, anemia, heart failure, other infections; Exclusion: Terminal at admission; already in a follow-up program with the geriatric team; living out of the municipality; transferred to another hospital department | High risk: Yes, diagnosis; Age 86.4 (6.2); Female: 62%; Race: NR; Living alone: 52%; Top 3: Urinary tract infection, other infections, pneumonia | Mortality; ED readmit; Timing: 30 days; Primary outcome: ED; Readmission rate | Objective: Low; Patient: NA
Medication Management
Mortimer, 2011^47^; Australia; 199; 2 | No assessment of risk; Referral only, no follow-up; Intervention delivered within ED | Inclusion: Aged ≥65 with chronic condition; aged ≥70 without chronic condition; Australasian triage category 2; Exclusion: Australasian triage category 1 (requiring immediate attention) | High risk: No; Age: 77.3 (NR); Female: 54%; Race: NR; Living alone: NR; Top 3: “Medical" patient, “surgical" patient, third condition NR | Patient experience ED readmission; Timing: Index, 14 & 28 days; Primary outcome: NR but power calculation for ED length of stay and ED readmission | Objective: High; Patient: High
Multi-Strategy Interventions
Discharge Planning PLUS Case Management/Transition of Care
Bond, 2014^45^; Canada; 1820; 2 | Assessment by care coordinator; Referral only, no follow-up; Intervention delivered within ED | Inclusion: Aged ≥65; ICD-10 discharge diagnosis of fall, fracture, sprain, strain, laceration, contusion, superficial injury, or bursitis; Exclusion: Discharge diagnosis of hip fracture or trimalleolar ankle fracture; patients who presented to ED for a musculoskeletal complaint within previous 30 days | High risk: Yes, diagnosis and falls; Age: 80.5 (8.0); Female: 70%; Race: NR; Living alone: NR; Top 3: NR | Hospitalization: At indexvisit; Hospitalization: After index visit ED readmission; Timing: 30 days; Primary outcome: Hospital admission rate at index visit | Objective: High; Patient: NA
Miller, 1996^46^; USA; 770; 2 | Assessment of risk; Referral and follow-up; Intervention delivered both within and after discharge from ED (“bridge”) | Inclusion: Aged ≥65; Exclusion: Acute illness too severe to permit participation; having <1 hour stay/departure without being seen; revisit by a previously included patient; lack of proxy for patients who did not appear to understand informed consent | High risk: No; Age 75.0 (7.0); Female: 60%; Race: White (67%),; Black/Other (32%); Living alone: 35% (only for intervention group; control data not provided); Top 3: Delirium, depression and undernutrition | Functional status:; ADL/IADL, quality of life; Mortality; Hospitalization: After index visit (# nights); ED readmission; Costs; Timing: 3 months; Primary outcome: NR | Objective: High; Patient: High

a Outcomes limited to those prioritized for this review.

b Objective outcomes (ie, non–patient-reported outcomes): mortality, hospitalization, ED readmission. Patient-reported outcomes: health-related quality of life, functional status, patient experience.

c Exclusion criteria shown are limited to those relevant to this review.

d Index refers to the emergency department visit during which study enrolment occurred.

Abbreviations: ADL=activities of daily living; COPD=chronic obstructive pulmonary disease; ED=emergency department; IADL=independent activities of daily living; ISAR=identification of seniors at risk; NA=not applicable; NR=not reported; SD=standard deviation; SF-36=short-form health assessment questionnaire; TIA=transient ischemic attack; UTI=urinary tract infection