# APPENDIX E Peer Review Comments

Question Text | Reviewer Number | Comment | Response
Are the objectives, scope, and methods for this review clearly described? | 1 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described? | 2 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described? | 3 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described? | 4 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described? | 7 | Yes | Acknowledged
Are the objectives, scope, and methods for this review clearly described? | 8 | Yes | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 1 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 2 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 3 | Yes - Reads as biased against studies that do not use the previously published 2014 guidelines or do not use conceptual model. | We respectfully disagree with this comment. In systematic reviews, bias is most likely to be introduced through study selection (search, eligibility criteria), or synthesis. Our search and eligibility criteria did not preferentially select for studies that used a conceptual model. Similarly, studies were included in syntheses of results without regard to the presence of a conceptual model. We have also added a note to the Research Gaps/Future Research section that there has not been sufficient time since publication of the 2014 Guidelines for hospitals to implement changes, evaluate the effects, and disseminate findings.
Is there any indication of bias in our synthesis of the evidence? | 4 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 7 | No | Acknowledged
Is there any indication of bias in our synthesis of the evidence? | 8 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 1 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 2 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 3 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 4 | Yes - As described more fully in “additional comments” below, there may be a limitation with the Search Strategy defined in Appendix B. Search term #1 required a study that defined itself as geriatric or a “aged care “study may have reduced the yield in the literature search as some controlled studies that compare emergency department management for medical conditions of aging do not necessarily define themselves as geriatric or “older adult” studies. | We thank the reviewer for this observation. It is possible that studies conducted on a particular condition (eg, delirium, falls) that disproportionately affect older adults could be missed if they were not coded as geriatric or aged care. However, the reviewer raises this as a hypothetical, without identifying any missed studies. We repeated the search using terms for delirium and falls. Only 2 unique citations were identified that were not captured by our original search strategy, suggesting that relevant studies are indexed (MeSH terms) using “aged care” terms. Neither citation met eligibility criteria. This test of our search strategy along with other methods to identify relevant studies (review of scoping and other reviews for relevant studies) give us confidence that we identified the eligible literature. Finally, as noted elsewhere in our response, our search strategy was discussed in collaboration with our operations partners. This report was commissioned to identify ED interventions that would be broadly applicable to older adults as opposed to focus on particular conditions or events.
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 7 | No | Acknowledged
Are there any [underlined: published] or [underlined: unpublished] studies that we may have overlooked? | 8 | No | Acknowledged
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Very informative and excellent report summarizing ED interventions on improving patient care, experience, and utilization outcomes for older adults. A report like this is much needed and if (shortened and) reframed as a journal manuscript, will likely be of high interest by emergency medicine and geriatrics journals and their readers. | Acknowledged
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Major recommendations:; Greater clarification in the methods section of how the review was conducted of each study – what was extracted and then “synthesized” would strengthen the paper and allow readers to understand how the review was conducted. Many of the categorizations, ratings (e.g., risk of bias) only come out in the results section and were not clarified in the methods for how these scores were generated (i.e., were these totally subjective in rating by reviewers?) | The Data Abstraction section of the Methods describes the major categories of data abstracted. In addition, Appendix A gives detailed definitions of the intervention elements abstracted and their definitions. We revised the report to consistently refer to risk of bias (elements described in the methods and Appendixes D and I), whereas the draft report described these elements inconsistently as risk of bias or study quality.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Minor concerns:; Pg. 1. GED Guidelines citation that this was issued by ACEP does not acknowledge the guidelines were also endorsed and issued by the American Geriatrics Society, Society for Academic Emergency Medicine, and Emergency Nurses Association. (1-3) | Thank you. These citations have been added to the background section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | 1. Carpenter CR, Bromley M, Caterino JM, et al. Optimal older adults emergency care: introducing multidisciplinary geriatric emergency department guidelines from the american college of emergency physicians, american geriatrics society, emergency nurses association, and society for academic emergency medicine. J Am Geriatr Soc. 2014;62(7):1360-1363. | This citation has been added to the background section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | 2. Carpenter CR, Bromley M, Caterino JM, et al. Optimal older adults emergency care: Introducing multidisciplinary geriatric emergency department guidelines from the American College of Emergency Physicians, American Geriatrics Society, Emergency Nurses Association, and Society for Academic Emergency Medicine. Acad Emerg Med. 2014;21(7):806-809. | This citation has been added to the background section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | 3. Carpenter CR, Bromley M, Caterino JM, et al. Optimal older adults emergency care: Introducing multidisciplinary geriatric emergency department guidelines from the American College of Emergency Physicians, American Geriatrics Society, Emergency Nurses Association, and Society for Academic Emergency Medicine. Ann Emerg Med. 2014;63(5):e1-3. | This citation has been added to the background section.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Was a strategy or framework for assessing interventions and programs developed prior to data abstraction from the eligible studies? (aside from patient characteristics, intervention structure, comparator, and outcomes? And aggregating outcomes for at least 3 studies?) (i.e., overall conceptual model the motivated the intervention – was this defined before or during the study reviews?) | Thank you for this comment. We have clarified that our conceptual framework was developed a priori and that our intervention strategies and components were also developed prior to data abstraction, in collaboration with our stakeholders and technical expert panel.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | The conceptual framework for geriatric emergency patient care (Figure 1) predisposing factors and outcomes for older adults that utilize the ED is excellent. | Acknowledged
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | How was risk of bias (ROB) measured? (Strength of Evidence is based on an AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews, but not there is no info for how ROB criteria were ascertained to give scores of low, unclear, vs. high ratings in the methods section). | In the draft report, ROB was referred to variably as study quality or ROB. We revised the report to consistently use the term “risk of bias.” The approach (EPOC criteria) is described in the Methods section (“Risk of Bias” subsection), and further details are given in Appendix D).
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Decision to examine effects of intervention on patients, clinicians, policymakers determined a priori? Tying these effects to the conceptual model proposed by the ESP around geriatric emergency patient care would be helpful. | Thank you for this comment. In our methods section, we have clarified that our conceptual framework was determined a priori. We have also added language to our Limitations section in which we note that the limited information reported by many studies prevented us from exploring the effects of patient- and provider-level intervention components on our chosen outcomes.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Were the 4 ED intervention strategies (pg.10) determined a priori to the review, or after the paper abstraction process? | Thank you for this comment. We have added language to clarify that intervention strategies were determined a priori.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Were ED intervention components determined a priori or during abstraction? | Thank you for this comment. We have added language to clarify that intervention components were determined a priori.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Figure 6 and 7 should include a legend describing the colored circles in the table. | We have added clarification describing the colored circles in the footer.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 1 | Is there a reference for the PICOTS framework? (pg. 33) | We added the following citation which describes the use of PICOTS framework for identifying research gaps.; Robinson KA, Akinyede O, Dutta T, Sawin VI, Li T, Spencer MR, Turkelson CM, Weston C. Framework for Determining Research Gaps During Systematic Review: Evaluation. Methods Research Report. (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-10061-I.) AHRQ Publication No. 13-EHC019-EF. Rockville, MD: Agency for Health care Research and Quality. February 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 2
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Congratulations to the research team on a tremendous accomplishment completing this review. There are many strengths: rigorous methodology, great conceptual model proposed. | Acknowledged
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Tremendous redundancy. I think I read 6 times that the papers evaluated did not refer to the 2014 published guidelines (and this is just one example). | Thank you. We edited carefully to streamline the report and reduce redundancy.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Lack of reported racial/ethnic/socioeconomic information in most papers is a bigger issue than the authors make it seem given the demographics of our VA population. | Thank you for this comment. We acknowledge that only 4 of 15 studies reported race for study participants. As noted in the PICOTS table of our Future Research section, the lack of this information limits the number of subgroup analyses that can be conducted. As noted, we believe the use of a comprehensive conceptual framework may encourage more complete reporting of participant characteristics, including race and other sociodemographic characteristics (ie, income, education) that may influence medical events and ED utilization.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Conclusions do not always line up with reported results. Needs to be exact alignment between reported findings and results, for example is it only bridge interventions that were successful or not? | Thank you for this comment. We have revised our Conclusion section to be more consistent with the reported results.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Should explicitly state which outcomes were primary outcomes for which the studies were designed with adequate statistical power to reject the null hypothesis versus those which measured the outcome as a secondary (exploratory) outcome. | Appendix F (Study Characteristics Tables) identifies the primary outcome for each study. For individual studies, we note when effects were imprecise. When grading the strength of evidence, we note when summary estimates of effect were imprecise and judged to cross decisional thresholds. We updated the key points to reflect this detail.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Paper would be stronger summarizing the previous reviews in the intro not at the end. | Thank you for this comment. We selected to highlight gaps of previous reviews in the Introduction and address our findings in context of these reviews later in the paper. As highlighted in the Introduction, no prior reviews examined multi-strategy interventions and/or attempted to identify intervention components.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Specific suggestions for improvement (some of these are big issues related to the above points and some are small points):; Page 1: Study selection – why “in brief”? This should be more detailed. RE enrolling older adults: did studies have to enroll ONLY older adults? What about interventions that included older adults but also included middle aged patients? | Detailed eligibility criteria are given in the body of the report and in Appendix C.; No studies enrolled mixed samples of older and younger patients. In the description of included studies (Results Section, Detailed Findings), we clarified that only older adults were enrolled.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 2 (and page 17): Term “best practices” not mentioned in the intro. Should either be mentioned in methods/part of “key question” (that currently only talks about interventions not “best practices”, or not included in top bullet. | Thank you for this comment. We have replaced the phrase “best practices” with “ED interventions.”
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Bullet 3 and 4 seem to contradict each other. Bullet 3 says only “bridge” interventions work, but bullet 4 talks about “ED” interventions possibly benefiting functional status. Does “ED” include “bridge” or mean ED only? Clarity of terminology in the bullets (and throughout) should be improved. | Thank you. We have reorganized the key points, adding greater specificity on potential benefits and using consistent language throughout the report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Bullet 6 (and this applies to Page 22): were any of these studies actually designed with enough statistical power to look at mortality as an outcome? If not, would just say that, rather than say the interventions did not affect mortality. Should be very clear whether these studies were designed with adequate power versus looking at mortality as a secondary outcome.(Comments for these bullets also apply to page 17 where the bullets are repeated). | We modified this key point to specify that no study selected mortality as the primary outcome.; We are unable to address whether studies were designed with sufficient statistical power to address each outcome. This would require specification of a clinically important difference and a power calculation for each outcome.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 4-5. What does “precise” mean? What does “indirect” mean? How was SOE and ROB determined? | By design, the Executive Summary does not give detailed definitions of terms. However, we have added a glossary that defines key terms. Details on the assessment of SOE and ROB are given in the Methods section of the main report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 5, line 24. What other reviews? References here would improve this para. I don’t see how this first sentence in this para is supported by the results of the presented analyses (it may be true but I don’t see this as a logical conclusion from the results). Seems like first implication (based on what I have read so far up to this para) should be that ED-focused interventions have been mostly unsuccessful. | Thank you for this comment. Prior research has suggested that bridge interventions, or those with planned contacts taking place both pre- and post-ED discharge, may be more effective. We have added a citation here to reflect this recommendation.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Related in same para (and on page 32): “improving outcomes for older ED users will be challenging” is a statement of the obvious and has nothing to do with the results of the analyses. | Thank you for this comment. We have removed this statement entirely from the Executive Summary and revised our language in the Discussion to suggest that future work should be longitudinal and transdisciplinary.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 5 – Research Gaps. One big gap that is not mentioned here is identifying an intervention that has a big meaningful effect size. | We agree and have outlined a future research agenda that we believe could contribute to identifying highly effective strategies.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 5. What basis do the authors have for concluding that using a conceptual model will improve the science? (As a health services researcher I completely agree that conceptual models are important, but I don’t see how this is a “conclusion” from the results.). Suggest reframing this as a suggestion/opinion on how to improve the state of the science moving forward. | We have added more information highlighting the potential value of a conceptual model in regards to its ability to depict hypothesized relationships between intervention strategies and outcomes of interest (ie, mechanisms of action).
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 6 line 22. “signal” is jargon (this comes up again at the end of the paper also). | Merriam-Webster defines “signal” as a sign or indication. Although accurate, we dropped this term.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 10 line 34. “Best practices” comes up again – what does this mean and how does it fit with the rest of the methods? | Thank you for this comment. As address earlier, we have replaced “best practices” with “intervention strategies” throughout the report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 12, line 9. Should reference and describe findings from ED geriatrics assessment/discharge planning intervention reviews. | Thank you for this comment. We have elected to focus this paragraph on the conceptual model and its potential to help tease apart intervention strategies and components not previously addressed in prior reports. Results from prior reviews, including those examining geriatric assessments and discharge planning interventions, are addressed in the Introduction and Discussion sections of the report.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Figure 1/Conceptual model is a strength of this review. | Acknowledged
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 13, line 12. What is a “scoping” review? | Scoping reviews are used to identify knowledge gaps, set research agendas, and identify implications for decision-making. Scoping studies differ from systematic reviews because authors do not typically assess the quality of included studies.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 14. Now I see where the terms “directness” and “precision” come from (AHRQ publication) but I still don’t know what these actually mean. Paper would be stronger with explanation/definition of each of these terms. | We added a glossary that defines key terms.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Pages 17-18: No studies with Veterans is stated twice in these 2 pages (and other times). | Thank you. We have addressed this redundancy.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Table 5, row 1 (study design). Not clear whether the 2nd line of text is a subset or an additional study. Is the cluster-randomized trial also considered one of the 8 randomized trials or is it a 9th RCT? Same with the non-randomized – is the pre-post considered one of the 5 nonrandomized? | The total number of studies is given in the column header. Except where noted in a footnote, all counts of studies are independent and sum to the total given in the column header.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | The finding that so many studies do not report race deserves more attention. | We thank the reviewer for this comment. We have added a statement to the PICOTS table of our Future Research section stating that the lack of this information prevented us from conducting subgroup analyses. We have also elaborated on the benefit of a conceptual model to take a more comprehensive view of ED use and explore how, if at all, sociodemographic factors, including race, income, and education, may impact ED use and outcomes.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 22, line 52 (and many other places throughout the manuscript): suggest replacing the word “evaluated” or “examined” with “measured” ie the study MEASURED the effect of the ED intervention (not evaluated or examined). | We considered these terms and edited the manuscript to consistently use the term “evaluated” as we think this best describes the goal of studies designed to determine the effects of ED strategies on the selected outcomes.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Figure 4 and 5. Clarify that column header R=randomized | The figures have been changed to clarify the column header.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Figure 6 and 7 are confusing for several reasons. Since the title has “bias” in the title it would seem that a plus sign would indicate more bias but at the same time more bias is undesirable so would that be red (bad)or green (good)? At a minimum need a legend/color scheme but also would be good if direction of bias and plus sign went same direction. “Objective” outcome is not correct term for non patient-reported outcomes. Suggest “administrative” or non-patient-reported. It is not clear how the summary “objective” and patient-reported outcomes ROB scores were calculated. | Thank you for this comment. These figures were created in Cochrane software using their standard visual approaches which are well understood in the SR community. We have added a footer to define the color/symbol scheme.; We agree that “non-patient reported” is a better term than “objective” but it is a noun-string that decreases readability. We now describe these as non-patient-reported outcomes but tell the reader we will use objective outcomes for readability.; Summary ROB ratings are not calculated. They are based on judgments after considering each of the items in the ROB assessment. We have added the definitions for low, unclear and high ROB.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 30, lines 13-14. Patients may be similar in level of acuity but likely to be dissimilar in terms of race/ethnicity/socioeconomic status. | Thank you for this comment. We have clarified that the patients in the identified studies may be medically similar to Veterans. We have expanded our section on “Applicability to Veterans” to highlight potential differences in race, ethnicity, and socioeconomic status.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Page 30, lines 26-27. I don’t understand what is meant here about low-intensity interventions having limited applicability? Are you trying to say that higher intensity interventions might have bigger impacts? | Thank you for this comment. We have clarified that low-intensity interventions were classified as being short in duration and having a limited number of patient contacts. We have also clarified that most studies examined low intensity interventions, thus limiting our results to our low intensity interventions in the ED.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report. | 3 | Thank you for the opportunity to participate in the review of this interesting project. | Acknowledged
| 4 | This VA ESP is an exceptionally well-written document that addresses a critical problem of great interest to the VHA, i.e., the need to provide high quality care to the many elderly individuals who use emergency services. The emergency department (ED) is a critical access point that offers important opportunities to improve care and avoid deleterious outcomes.; The document was developed using a standardized protocol to conduct the literature synthesis, which is a strength. The mission of this ESP review is reported as follows: To build on the ACEP Geriatric Emergency Department Guidelines published in 2014 that provides a template for many aspects to ER practice, education and assessment and evaluation to improve care for older adults. It is additionally stated that this document is intended to be used by the VHA Offices of Geriatrics and Extended Care Operations and Emergency Medicine to evaluate best practices in emergency care. | Thank you for this feedback.
| 4 | As noted below, the results from this synthesis may be somewhat limited in their ability to meet the goals stated above, and this may be related to the search design for the literature review.; The search terms selected for this synthesis, as outlined in excellent detail in Appendix B, might be unable to capture all relevant papers. Review of these search terms suggests that they captured the constructs of 1) geriatric focused study 2) ED service examined in the study 3) Absence of a focus on children or adolescents and 4) Presence of clinical trial/clinical intervention comparison methods. Including these four features resulted in only nine randomized trials and six non-randomized trials. This very small number of studies greatly reduced the authors’ ability to derive helpful conclusions for future guidelines.; A possible source of this small yield could be the requirement for explicit “geriatric” terms in the search – for example, the vast majority of ED visits are related to the top contributors to aging complications: Falls/syncope, heart failure, delirium. While these conditions occur almost exclusively in the elderly, a comparative study of best practices for their ED treatment may or may not define itself as “geriatric.” For example, there is a superb conceptual model from the Society of Academic Emergency Medicine and the Heart Failure Society to guide ED management of heart failure in the paper: Collins S. Journal of Cardiac Failure Vol. 21 No. 1 2015. Despite the paper noting that this is addressing a critical need for the growing population of older adults, the paper does not identify itself as geriatric per se. Since heart failure occurs almost entirely in the geriatric population, this paper is one example of a study that may offer insights to the topic at hand that could have been confirmed as a study of older adults in the literature review while not noting itself as a “geriatric” or “older adult” study. The main issue at hand is that ED services are invariably applied and studied to diseases of aging, but the denotation of “geriatric” is a subspecialty designation that is not available in all ED settings. Despite this, a full synthesis to understand best practices in the ED for older adults should at least be aware of this limitation, even if the ultimate decision is to focus only on “geriatric” specialty services.; It is very understandable that the authors do not want to limit the ESP to specific medical conditions and the authors are absolutely correct that an over-focus on only medical signs and diagnostic tests without a full conceptual model that includes social factors can lead to major failures to address critical needs. On the other hand, the acute medical diagnosis has such a great effect on the nature of the ED service and follow-up quality that the medical condition cannot be excluded entirely. For this reason, the ACEP Guidelines do specifically provide guidance on some of the top ED conditions that are intervenable. That is, the ACEP specifically addresses falls, urinary catheters/UTI, complex medication use/polypharmacy, delirium and palliative care needs. While this submitted ESP does take a broad-spectrum approach with good reason to avoid specific conditions, unfortunately the outcome obtained by the ESP avoiding overly medically-focused studies, was that the results were very small. This occurrence is important to note since it is meaningful that some bit of medical need must be in the model, since it accounts for variance both in seeking care and after-care needs. | The comment regarding the “small yield” resulting from our search strategy was addressed above.; This evidence synthesis was requested by our operational partners to evaluate strategies that would apply generally to older adults presenting to VA EDs, rather than older adults with specific conditions. Older Veterans have, on average, 4 chronic conditions, lower physical and mental health-related quality-of-life, and higher rates of functional impairment compared to non-Veterans. In an effort to meet the needs of a highly complex patient population, our operational partners commissioned this report to evaluate general strategies that would be applicable to the VA’s patient population.; Our description of studies table (Appendix F) describes the 3 most frequent conditions/presenting symptoms reported in each study. We summarize this information in the results subsection “Description of Included Studies for ED Interventions for Older Adults.” We agree that evidence syntheses on strategies to address specific conditions in older adults would be valuable, but this would have been inconsistent with our operational partners’ guidance.
| 4 | The current yield in this synthesis does not give the field good fodder to grow into evidence-based practices for the VHA emergency services. To be truly patient-centered and provide precision care, EBPs must at least address the medical needs of the specific patient somewhat. Consequently, this ESP unfortunately does not meet its goal of expanding upon the ACEP document.; So the happy medium may most likely be achieved by taking a similar approach to the ACEP and at least examine the most common and intervenable conditions that are likely to bring Veterans to the ED. For example, the ACEP has a well-crafted series of potential interventions for patients who have suffered a fall, this includes equipment, care strategies, interdisciplinary interventions and quality measures related to care for older patients with falls who have been in the ED. Following this lead, this ESP analysis could have provided a literature synthesis (presently absent for the ACEP report) regarding the literature on randomized trials comparing ED interventions for patients with falls. For the search terms in the literature synthesis, this would involve adding (instead of the geriatric terms in #1), the presence of hip fracture, other fracture, syncope, falls, dizziness, unsteady gait, other injury including head injury from falls, etc. This type of ESP approach may lead to more operational outcomes. Without more to offer from this ESP, is does not provide a substantial advancement over the ACEP guidelines | The goal of this review was to review the evidence to determine the effectiveness of emergency department (ED) interventions for improving clinical, patient experience, and utilization outcomes in older adults (age ≥65). We did not have a goal of “expanding upon the ACEP document.”; Although the ACEP guidelines provide practical consensus-based recommendations, we agree that evidence syntheses that summarize the evidence for common geriatric conditions could be of great value. However, our review was not commissioned for this purpose. We have strived to make it clear that our findings apply only to strategies that are not condition-specific.
| 4 | This is not to say that this ESP information is not useful, it is good information to see what was found. But the results did not lead to any definitive steps for evidence based practice as there is no clear signal reported other than multi-strategy or case-management type interventions may reduce ED re-admissions. Unfortunately, this finding does not give compelling support to next steps as there is no clear operational strategy derivable from this finding. The authors mention a number of times that a clear conceptual model is needed to conduct better research, but the framework proposed in Figure 1 on page 12 is challenging to interpret regarding how it may work as it jumps from “older adults presenting to ED” directly to three different intervention components, it is missing the information gathering, interview, examination and diagnostic piece in the middle. It is commendable that the model includes the socio-demographic and other preexisting factors the patient brings to the ED, but it is missing the fact that the patient’s clinical reason for presenting does matter in the model. Establishing a clinical/medical understanding of the individual patient cannot be skipped over – and consequently it is difficult to determine how this model can be applied as it appears to lack specificity that is essential for the patient centered and precision-care world that we live in. | We thank the reviewer for this comment and agree that critical steps in the care process are not depicted in our model. However, conceptual models within systematic reviews are not meant to be all-encompassing. The model shown in our paper was a purposeful simplification of what we believe all causal pathways to be. We agree that a more robust model should be developed prior to intervention design and dissemination.
| 4 | Another comment may be helpful regarding the use of conceptual frameworks (generally speaking) in research: It may be useful to appreciate that the emphasis on conceptual models as a requisite for research is largely unique to the VHA in current times. Outside DOD and VHA services research, other funding agencies evaluate research based on scientific premise and rationale, while conceptual framework language is more often reserved for studies that are speculative - or preliminary work based on theory such as projects for career awards, pilot grants and preliminary research awards. Consequently, it may not always be a deficiency in a research study not to begin with a conceptual model diagram, but rather just a difference in approach between different funding sources for research. | Thank you for this comment. We believe that conceptual models provide tremendous value in identifying causal processes, including mediating mechanisms and moderating effects, particularly in areas of research where such information has not been well-established. We have revised our language to better emphasize that the presence of a conceptual model was not a requirement for inclusion into our study and did not suggest a deficiency when not present.
| 7
| 8 | Appreciate the opportunity to read this. | Acknowledged