# APPENDIX D Study Risk of Bias Assessment

For full study citations, please refer to the report’s main reference list.

The following abbreviations are used in the risk of bias tables in this appendix:

- 1=Randomization adequate
- 2=Allocation concealment
- 3=Baseline measure similar
- 4=Baseline-provider contamination
- 5=Detection bias (objective outcome)
- 6=Detection bias (patient-reported outcome)
- 7=Incomplete outcome
- 8=Protection against contamination
- 9=Selective outcomes reporting
- 10=Other bias
- 11=Overall objective outcome
- 12=Overall patient-reported outcome
- LR=low risk of bias; HR=high risk of bias; NR=not reported; NA=not applicable; UR=Unclear risk of bias

## Randomized Studies

Study | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12
Basic, 2005^34^ | LR | LR | HR | UR | LR | HR | HR | LR | LR | LR | HR | HR
Biese, 2014^35^ | UR | HR | UR | HR | LR | HR | HR | UR | LR | HR | HR | HR
Biese, 2017^36^ | LR | LR | UR | UR | LR | HR | LR | UR | LR | UR | UR | HR
Caplan, 2004^37^ | LR | LR | LR | UR | LR | HR | LR | LR | LR | LR | LR | UR
Eklund, 2013^38^ | UR | LR | LR | UR | NR | HR | LR | UR | LR | LR | NA | HR
Gagnon, 1999^39^ | LR | LR | LR | NR | LR | UR | LR | HR | LR | UR | UR | UR
McCusker, 2001^40^ | LR | LR | LR | UR | LR | LR | LR | LR | LR | UR | LR | LR
Mion, 2003^41^ | LR | LR | LR | UR | LR | LR | LR | LR | LR | LR | LR | LR
Runciman, 1996^42^ | UR | UR | HR | UR | UR | UR | UR | LR | LR | LR | UR | UR

Summary Ratings Across Randomized Studies for Each Risk of Bias Domain

^a^White space indicates items that were not applicable.

## Nonrandomized Studies

Study | 1 | 2 | 3 | 4 | 5 | 6 | 7 | 8 | 9 | 10 | 11 | 12
Arendts, 2012^43^ | HR | HR | LR | UR | LR | NR | LR | LR | LR | LR | HR | NA
Arendts, 2013^44^ | HR | HR | UR | UR | LR | NR | LR | LR | LR | HR | HR | NA
Bond, 2014^45^ | HR | LR | UR | UR | LR | NR | LR | LR | LR | LR | HR | NA
Miller, 1996^46^ | HR | HR | UR | NR | LR | HR | HR | LR | LR | HR | HR | HR
Mortimer, 2011^47^ | HR | HR | UR | UR | LR | HR | LR | HR | LR | LR | HR | HR
Pedersen, 2016^48^ | LR | LR | LR | UR | LR | NR | LR | LR | LR | LR | LR | NA

Summary Ratings for Nonrandomized Studies Across Each Risk of Bias Domain

^a^White space indicates items that were not applicable.