# APPENDIX C Study Selection

## Study Eligibility Criteria

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Adults aged ≥65 who present to an emergency department (ED) for acute, urgent, or emergency care | - Studies enrolling mixed samples with <70% of participants aged ‡65; - Studies enrolling condition-specific subgroups of older adults (eg, with a single presenting condition such as “falls” or “dementia”)
Interventions | 4 intervention strategies (including those that use 1 or more strategies or are “multi-strategy”) (see Appendix A for full definitions); - Discharge planning; - Case management/transition of care; - Medication safety/medication review; - Strategies designed or guided by the 2014 Geriatric Emergency Department Guidelines^16–18^ | - Interventions focused exclusively on risk or functional assessment instruments; otherwise-eligible interventions may utilize risk or functional assessment instruments to identify patients; - Transition planning for patients who reside in nursing homes or involving transfers to other hospitals or hospital settings; - Interventions focused on a single condition (eg, dementia) instead of general care of older adults in ED; - Interventions focused on shared decision-making, including related to medication selection and management; - Interventions performed after the final decision to admit the older adult to hospital or after discharge had been made
Comparator | Usual or enhanced ED care (eg, information or educational control) | No comparator
Outcomes | - Clinical outcomes: Overall functional status (or subdomains of physical or mental functioning), health-related quality of life, mortality^a^; - Patient satisfaction/experience: Any validated measure of patient satisfaction/experience; - Care utilization: ED readmission; hospitalization related to index ED visit; hospital admission rates (following ED discharge) | - Laboratory parameters (eg, A1c, cholesterol levels); - Disease-specific symptoms (eg, depressive symptoms, shortness of breath); - Guideline adherence; - Prescribing behaviors; - Patient/caregiver knowledge
Timing | - Time points that are logically affected by the intervention and are clinically relevant, prioritizing short (eg, 30 days) and longer (eg, 90 days) time points; - For patient satisfaction, within 30 days of admission/discharge | None
Setting | Emergency departments
Study design | - Randomized controlled trials; - Quasi-experimental studies (prospective controlled designs: controlled nonrandomized trial, before-after cohort study, case-matched controlled; interrupted time-series designs); - All studies must include an eligible comparator per EPOC criteria^29^ | - Retrospective studies; - Cross-sectional designed studies; - Cost-effectiveness analyses; - Program descriptions
Publication type | - English-language publications; - 1990 to current date; - OECD countries (North America, Australia, New Zealand, Japan, South Korea, Israel, Chile, Turkey, and Europe) | - Non-English language; - Not a full publication in a peer-reviewed journal; - Meeting abstracts, letters, editorials, and dissertations.; - Pilot studies or sample sizes <20

a Given the potential array of conditions, disease-specific measures of severity and symptoms are not particularly practical or helpful to decision making; therefore we chose concepts that cut across conditions.

Abbreviations: A1c=glycosylated hemoglobin; ED=emergency department; EPOC=Effective Practice and Organisation of Care; OECD=Organisation for Economic Co-operation and Development