# APPENDIX A Intervention Strategies and Components

For full study citations in this appendix, please refer to the report’s main reference list.

## Intervention Strategies

Strategy | Description
Discharge planning | Discharge planning involves the process of thinking about and formalizing a plan of care prior to a patient’s discharge from the ED. In this instance, discharge planning is defined as being time-limited, taking place fully within the ED (prior to discharge). Discharge planning may incorporate 1 or more of the following: geriatric consultation or geriatric assessment in the ED, written information provided to the patient/caregiver, patient/caregiver education, and/or a follow-up plan. Although not required for discharge planning, the geriatric assessment is a multidimensional, multidisciplinary assessment designed to evaluate an older person’s functional ability, physical health, cognition and mental health, and socioenvironmental circumstances. The geriatric assessment may include a geriatrician or geriatric trained nurse practitioner or physician assistant and may be a focused assessment that is customized for ED settings. Although 1 or more providers may conduct an assessment and make recommendations, the responsibility to initiate, coordinate, and secure any post-ED services or recommendations typically rests with the patient and/or caregiver.
Case management | Case management occurs over time and helps to support successful transition of care from the ED to the post-ED settings. Case management activities often take place across settings, initially beginning in the ED and continuing after discharge. Case management may incorporate all the activities which a physician or other health care professional performs to insure the coordination of the medical services required by a patient to successfully transition from the ED setting to home (or other residential facility). In this instance, we defined case management more narrowly to require a non-physician, either onsite in the ED or offsite, who is involved in coordinating follow-up care that is related to an ED visit. This may include home-based services and/or referral to primary care providers, specialists, or other community-based resources and services. Unlike discharge planning in which the patient or caregiver may be responsible for identifying and securing services, in case management, the major responsibility and coordination rests with the provider (eg, an order for physical therapy).
Medication safety or management | These are interventions that assist patients or caregivers in reviewing, managing, and monitoring drug therapy for older adults with chronic conditions. More basic interventions may include a simple review or reconciliation of medications. More involved interventions may incorporate a clinical pharmacist or other expert in drug therapy, and/or computerized interventions so long as they are conducted in real time (during patient’s ED admission). Interventions may be targeted to the clinician, patient and/or the family as long as they focus on the proper selection of medications, reduction in polypharmacy or medication errors, or use of medications. These interventions would not include shared decision-making approaches to choosing 1 treatment versus another.
Geriatric Emergency Departments | These are EDs designed or adapted to conform to 2014 American College of Emergency Physicians Guidelines.^18^

## Patient-Focused Intervention Components

PATIENT-FOCUSED INTERVENTION COMPONENTS; (Information is collected from or provided to the patient or caregiver)
Assessment and screening
Geriatric assessment | A multidimensional interdisciplinary evaluation to ensure that problems are identified, quantified, and managed appropriately. Common elements include assessment of medical, psychological, biopsychosocial, functional, cognitive, and environmental capacity. Results from the assessment may be used to inform other elements of discharge planning.
High-risk screening | Use of 1 or more risk-screening tool(s) to evaluate a specific risk factor, condition, or potential outcome. Risk screening tools are typically brief and shorter in nature than a comprehensive, multidimensional assessment.
Patient and/or caregiver education or support
Patient education | Key information provided in writing or explained to patient and/or caregiver. The information provided is related to diagnosis or treatment but does not encourage specific behavior change.
Self-management | Patient-directed education or coaching that focuses on enhancing the patient’s ability to self-manage care needs. This may include education or coaching around specific behavior(s) (eg, weight control action plan) and/or disease specific information (eg, congestive heart failure action plan).
Caregiver education | Education directed toward the caregiver, which may include any of the following: basic disease education, behavior management strategies, guidance on how to support the patient in self-care, or information on how to provide direct care, including information related to condition, symptoms, treatment, or medication management.
Caregiver support | Supportive counseling or guidance focused on self-care, coping skills to manage caregiver burden and expectations, tips on identifying local resources, communication skills, etc.
Shared decision-making | Decision-making around testing, treatment, and/or discharge are shared between different individuals, potentially including the patient and/or caregiver. May include use of a decision aid.^29^

Intervention
Medication intervention | Medication reconciliation or special education aimed at improving medication understanding or adherence.^26^
Rehabilitation intervention | Patient receives occupational and/or physical therapy aimed at improving functional status.
Telemonitoring | Use of remote technology designed for the patient to transmit objective measures of health status with or without connected subjective assessment (eg, health buddy).^26^

## Provider- or Service-Focused Intervention Components

PROVIDER AND/OR SYSTEM-FOCUSED INTERVENTION COMPONENTS; (related to care delivery or care process)
Follow-up call or visit
Patient hotline and/or patient-initiated appointment systems | An open line for patient-initiated communication.^26^ Systems that enable patients to make urgent appointments when they feel they cannot manage their condition or where something has changed unexpectedly.^29^
Follow-up visit scheduled | A follow-up visit is scheduled prior to discharge from ED and/or prior to the end of the intervention period.
Follow-up communication | ED provider or intervention staff initiate telephone follow-up communication after discharge from the ED.
Follow-up visit completed | In-person follow-up visit completed during the course of the intervention period.
Home visit | In-person visit to patient’s place of residence by 1 or more intervention providers.
Referral to services
Referral(s) to primary care | ED provider initiates and/or recommends referral to primary care.
Referral(s) to medical specialist(s) | ED provider initiatives and/or recommends referral to medical specialist(s).
Referral(s) to home or community-based services | ED provider initiates and/or recommends referral to 1 or more home or community-based services. Examples include physical/occupational therapy, meal delivery, home-based primary care, or adult day health care.

Continuity of care/care coordination
Communication between providers (“clinician continuity”) | Processes that ensure the responsibility of care is passed from 1 provider to another. This may include increased provider presence before and after ED discharge, verbal or written communication between providers, strategic follow-up with primary clinician after discharge, or the involvement of a “bridging” clinician.; Increased provider presence before and after ED discharge; may include involvement of PCP in patient care or strategic follow-up with inpatient clinician after discharge or “bridging” clinician.^26^
Interdisciplinary care team meeting | Team meeting as part of discharge planning or ongoing case management.

## Emergency Department Structure and Procedures

EMERGENCY DEPARTMENT STRUCTURE AND PROCEDURES; Components designed and delivered to be in accordance with 2014 Geriatric Emergency Department Guidelines^18^
Staffing/administration | Presence of Geriatric Emergency Department Medical Director or Nurse Manager.
Follow-up and transition of care | Detailed procedures on how to provide age-friendly discharge planning within ED and appropriate referrals to post-ED services in the community.
Provider education | A formal, competency-based educational program designed to educate staff on the needs of older adults.
Quality improvement | Implementation of a formal quality improvement (QI) program designed to collect and monitor data related to program success.
Equipment and supplies | Structural and/or physical modifications to best support unique functional, clinical, and behavioral needs of older adults.; Improvements may include furniture, special equipment, visual orientation improvements, lighting, acoustic orientation.
Policies, procedures, and protocols | Changes to local policies and procedures.

## Other Characteristics of the Intervention Structure

Timing and setting
Pre-discharge (within ED) | Intervention is intentionally designed to be initiated and completed within the ED, prior to patient’s discharge.
Post-discharge (after leaving ED) | Patient is identified while in the ED (or immediately after discharge) but intervention is initiated and completed after patient is discharged from ED. Patient may or may not have face-to-face contact with the provider or interventionist.
Both pre- and post-discharge (“bridge”) | The intervention is intentionally designed so that elements take place both before [underlined: and] after discharge from the ED. The intervention is designed to have multiple points of contact.

Target of the intervention
Patient | The patient is the main recipient of any assessment or intervention.
Caregiver/family member | One or more caregivers are actively addressed in the intervention as a part of specified caregiver education or support.
Provider | Intervention is focused on training the provider and/or making adjustments to provider’s workflow or responsibilities. This does NOT refer to simply involving provider(s) to deliver intervention components.

How were intervention sessions delivered?
Mode of delivery | Intervention sessions were delivered via phone or in-person.
Planned contacts/sessions | The number of contacts/sessions the authors planned, or intended to happen, in the study.
Actual contacts/sessions | The number of contacts/sessions actually delivered in the study.
Type(s) of providers | The type(s) of provider(s) to deliver the intervention (eg, physician, nurse, social worker, case manager, physical or occupational therapist)