# Acknowledgments

This topic was developed in response to a nomination by Dr. Thomas Edes, Executive Director, VHA Geriatrics and Extended Care Operations, and Dr. Chad Kessler, Director, VHA Emergency Medicine, for the purpose of identifying and evaluating intervention strategies in emergency care for older adults and with the goal of implementation across 141 VA emergency departments (EDs) and urgent care centers (UCCs). The scope was further developed with input from the topic nominators (ie, operational partners), the ESP Coordinating Center, the review team, and the technical expert panel (TEP).

In designing the study questions and methodology at the outset of this report, the ESP consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

The authors gratefully acknowledge the following individuals for their contributions to this project:

## Operational Partners

Operational partners are system-level stakeholders who have requested the report to inform decision-making. They recommend TEP participants; assure VA relevance; help develop and approve final project scope and timeframe for completion; provide feedback on draft report; and provide consultation on strategies for dissemination of the report to field and relevant groups.

- Chad Kessler, MD
  National Program Director
  VHA Emergency Medicine
- Thomas Edes, MD
  Director
  VHA Geriatrics and Extended Care Operations
- Kenneth Shay, MD
  Director of Geriatrics Programs,
  VHA Geriatrics and Extended Care Services

## Technical Expert Panel (TEP)

To ensure robust, scientifically relevant work, the TEP guides topic refinement; provides input on key questions and eligibility criteria, advises on substantive issues or possibly overlooked areas of research; assures VA relevance; and provides feedback on work in progress. TEP members are listed below:

- Laura Taylor, LSCSW
  National Director, Social Work
  Department of Veterans Affairs
  Washington, DC
- Kevin Biese MD, MAT
  Vice Chair of Academic Affairs, Department of Emergency Medicine
  University of North Carolina at Chapel Hill
  Chapel Hill, NC
- Catherine A. Sarkisian MD, MSHS
  Staff Physician and Professor VA Greater Los Angeles Healthcare System GRECC
  David Geffen School of Medicine at University of California
  Los Angeles, CA
- Ula Hwang MD
  Associate Professor
  James J. Peters VAMC, Bronx, NY
  Icahn School of Medicine at Mount Sinai
  New York, NY

## Peer Reviewers

The Coordinating Center sought input from external peer reviewers to review the draft report and provide feedback on the objectives, scope, methods used, perception of bias, and omitted evidence. Peer reviewers must disclose any relevant financial or nonfinancial conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The Coordinating Center and the ESP Center work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.