# SUMMARY AND DISCUSSION

The principal conclusions of this systematic review are that the evidence is insufficient to support conclusions that CES has clinically important effects on headache, fibromyalgia, neuromuscular pain, depression, PTSD, or insomnia. There is low-strength evidence for a possible beneficial effect of modest size in patients who have anxiety with depression. CES is probably safe, in that no serious side effects have been reported, although reporting bias is present.

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1 Compared to usual care, what is the effectiveness of cranial electrical stimulation (CES) for the following conditions: chronic pain, depression, anxiety, PTSD, and insomnia?

CES may have a modest beneficial effect on symptoms of anxiety and depression in selected patients (SOE = LOW).

### Key Question 2 Compared to usual care, what are the risks of cranial electrical stimulation (CES) for the following conditions: chronic pain, depression, anxiety, PTSD, and insomnia?

CES does not cause serious adverse events but does cause certain minor symptoms (SOE = LOW).

## LIMITATIONS

### Publication Bias

We were not able to test for publication bias and can make no conclusions about its possible existence.

### Study Quality

The principal limitation to this review is the quality of the original RCTs. With all RCTs at high risk of bias, even the few signals of benefits are suspect.

### Heterogeneity

Heterogeneity is a limitation of this review as there were too few studies of the same patient and treatment to support statistical pooling.

### Applicability of Findings to the VA Population

Several studies were specifically of VA populations and for those studies the applicability of findings is direct. Many other studies, however enrolled populations that differ from VA in gender and probably comorbidities (probably fewer comorbidities than VA populations) rendering their applicability to VA only moderate.

## RESEARCH GAPS/FUTURE RESEARCH

The biggest research gap and need for future research is adequately blinded studies of sufficient size to detect clinical benefits of moderate size. While the sample size depends on the specific outcome being assessed, a reasonable rule-of-thumb would be 60 patients per group. Given that VA has many patients with pain, depression, anxiety, PTSD, and insomnia, and given that these studies may be relatively short in duration (6 months), it should be very feasible for VA to mount a program of research to answer the questions about effectiveness and safety, and answer these questions within a few years (2 – 4 years). As part of this evaluation, it would also be useful to understand whether any possible benefit persists after treatment discontinuation, or whether relapse in symptoms occur, and the timing of relapse. If CES is shown to have benefit compared to sham, then comparative effectiveness studies that assess CES compared to other proven active therapies for these conditions is warranted. Finally, long-term studies of safety may be needed.

## CONCLUSIONS

The evidence for the effectiveness and safety of CES is sparse. There is low strength evidence of a modest benefit in patients with anxiety and depression. CES is probably safe, but strength of evidence is low since few RCTs report adverse events. It should be feasible for VA to obtain better quality data to answer these questions through a series of RCTs with adequate blinding.