# REFERENCES

1 Guleyupoglu B, Schestatsky P, Edwards D, Fregni F, Bikson M. Classification of methods in transcranial electrical stimulation (tES) and evolving strategy from historical approaches to contemporary innovations. Journal of neuroscience methods. 2013;219(2):297-311.23954780
2 Klawansky S, Yeung A, Berkey C, Shah N, Phan H, Chalmers TC. Meta-analysis of randomized controlled trials of cranial electrostimulation. Efficacy in treating selected psychological and physiological conditions. The Journal of nervous and mental disease. 1995;183(7):478-484.7623022
3 Kavirajan HC, Lueck K, Chuang K. Alternating current cranial electrotherapy stimulation (CES) for depression. The Cochrane database of systematic reviews. 2014;7:Cd010521.
4 Mindes J, Dubin MJ, Altemus M, eds. Cranial electrical stimulation. New York, NY: Springer Science + Business Media; 2015.
5 Kirsch DL, Price LR, Nichols F, Marksberry JA, Platoni KT. Military service member and veteran self reports of efficacy of cranial electrotherapy stimulation for anxiety, posttraumatic stress disorder, insomnia, and depression. US Army Medical Department journal. 2014:46-54.25830798
6 Tan G, Dao TK, Smith DL, Robinson A, Jensen MP. Incorporating complementary and alternative medicine (CAM) therapies to expand psychological services to veterans suffering from chronic pain. Psychological Services. 2010;7(3):148-161.
7 Barclay TH, Barclay RD. A clinical trial of cranial electrotherapy stimulation for anxiety and comorbid depression. Journal of affective disorders. 2014;164:171-177.24856571
8 Lande RG, Gragnani C. Efficacy of cranial electric stimulation for the treatment of insomnia: a randomized pilot study. Complementary therapies in medicine. 2013;21(1):8-13.23374200
9 Taylor AG, Anderson JG, Riedel SL, Lewis JE, Kinser PA, Bourguignon C. Cranial electrical stimulation improves symptoms and functional status in individuals with fibromyalgia. Pain management nursing : official journal of the American Society of Pain Management Nurses. 2013;14(4):327-335.24315255
10 Higgins JP, Altman DG, Gøtzsche PC, . The Cochrane Collaboration's tool for assessing risk of bias in randomised trials. Bmj. 2011;343:d5928.22008217
11 GRADE working group. 2014; http://www.gradeworkinggroup.org/. Accessed 09/25/15.
12 Tietjen G, Thotakura S, Singh J, . Headache prevention with cranial electrotherapy stimulation in chronic migraine. A randomized controlled trial. Cephalalgia. 2013;33(11):963-964. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/955/CN-01006955/frame.html.
13 Solomon S, Elkind A, Freitag F, . Safety and effectiveness of cranial electrotherapy in the treatment of tension headache. Headache. 1989;29(7):445-450.2668227
14 Taylor AG, Anderson JG, Riedel SL, Lewis JE, Bourguignon C. A randomized, controlled, double-blind pilot study of the effects of cranial electrical stimulation on activity in brain pain processing regions in individuals with fibromyalgia. Explore (New York, NY). 2013;9(1):32-40.
15 Lichtbroun AS, Raicer MM, Smith RB. The treatment of fibromyalgia with cranial electrotherapy stimulation. Journal of clinical rheumatology : practical reports on rheumatic & musculoskeletal diseases. 2001;7(2):72-78; discussion 78.17039098
16 Tan G, Rintala DH, Jensen MP, . Efficacy of cranial electrotherapy stimulation for neuropathic pain following spinal cord injury: a multi-site randomized controlled trial with a secondary 6-month open-label phase. The journal of spinal cord medicine. 2011;34(3):285-296.21756567
17 Tan G, Rintala DH, Thornby JI, Yang J, Wade W, Vasilev C. Using cranial electrotherapy stimulation to treat pain associated with spinal cord injury. Journal of rehabilitation research and development. 2006;43(4):461-474.17123186
18 Tan G, Monga T, Thornby J. Efficacy of microcurrent electrical stimulation on pain severity, psychological distress, and disability. American Journal of Pain Management. 2000;10(1):35-44.
19 Solomon S, Guglielmo KM. Treatment of headache by transcutaneous electrical stimulation. Headache. 1985;25(1):12-15.3871754
20 Heffernan M. The effect of variable microcurrents on EEG spectrum and pain control. Canadian Journal of Clinical Medicine. 1997;4(10):4-11.
21 Cork RC, Wood P, Ming N, Shepherd C, Eddy J, Price L. The effect of cranial electrotherapy stimulation (CES) on pain associated with fibromyalgia. Internet Journal of Anesthesiology. 2004;8(2):15p. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/576/CN-00633576/frame.html.
22 Katsnelson Y, Khokhlov A, Tsvetkov V, Bartoo G, Bartoo M. Temporary pain relief using transcranial electrotherapy stimulation: results of a randomized, double-blind pilot study. Engineering in Medicine and Biology Society, 2004 IEMBS'04 26th Annual International Conference of the IEEE. 2004;2:4087-4090.
23 Rintala DH, Tan G, Willson P, Bryant MS, Lai EC. Feasibility of using cranial electrotherapy stimulation for pain in persons with Parkinson's disease. Parkinson's disease. 2010;2010:569154.
24 Gabis L, Shklar B, Geva D. Immediate influence of transcranial electrostimulation on pain and beta-endorphin blood levels: an active placebo-controlled study. American journal of physical medicine & rehabilitation / Association of Academic Physiatrists. 2003;82(2):81-85. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/870/CN-00412870/frame.html.
25 Gabis L, Shklar B, Baruch YK, Raz R, Gabis E, Geva D. Pain reduction using transcranial electrostimulation: a double blind “active placebo” controlled trial. Journal of rehabilitation medicine. 2009;41(4):256-261. http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/258/CN-00682258/frame.html.19247545
26 Mischoulon D, De Jong MF, Vitolo OV, . Efficacy and safety of a form of cranial electrical stimulation (CES) as an add-on intervention for treatment-resistant major depressive disorder: A three week double blind pilot study. Journal of psychiatric research. 2015;70:98-105.26424428
27 McClure D, Greenman SC, Koppolu SS, Varvara M, Yaseen ZS, Galynker, II. A Pilot Study of Safety and Efficacy of Cranial Electrotherapy Stimulation in Treatment of Bipolar II Depression. The Journal of nervous and mental disease. 2015;203(11):827-835.26414234
28 Turner MD Efficacy of Cranial Electrotherapy Stimulation in the treatment of depression: A pilot study. Dissertation Abstracts International: Section B: The Sciences and Engineering S2- Dissertation Abstracts International. 2016;76(8-B(E)).
29 Hearst ED, Cloninger CR, Crews EL, Cadoret RJ Electrosleep therapy: a double-blind trial. Arch Gen Psychiatry. 1974;30(4):463-466.4592898
30 Feighner JP, Brown SL, Olivier JE Electrosleep therapy. A controlled double blind study. The Journal of nervous and mental disease. 1973;157(2):121-128.4724809
31 Rosenthal SH Electrosleep: a double-blind clinical study. Biological psychiatry. 1972;4(2):179-185.4554818
32 Scallet A, Cloninger CR, Othmer E The management of chronic hysteria: a review and double-blind trial of electrosleep and other relaxation methods. Dis Nerv Syst. 1976;37(6):347-353.776551
33 Weiss MF The treatment of insomnia through the use of electrosleep: an EEG study. The Journal of nervous and mental disease. 1973;157(2):108-120.4146811
34 Moore JA, Mellor CS, Standage KF, Strong H A double-blind study of electrosleep for anxiety and insomnia. Biological psychiatry. 1975;10(1):59-63.1091305
35 Gibson TH, O'Hair DE Cranial application of low level transcranial electrotherapy vs. relaxation instruction in anxious patients. American Journal of Electromedicine. 1987;4(1):18-21.
36 Cartwright RD, Weiss MF The effects of electrosleep on insomnia revisited. The Journal of nervous and mental disease. 1975;161(2):134-137.1097597