# METHODS

## TOPIC DEVELOPMENT

This topic was developed in response to a nomination by Joyce Edmondson, PSAS Clinical Program Manager, Office of Rehabilitation and Prosthetic Services (10P4R) and Friedhelm Sandbrink, MD, Deputy National Director, Pain Management, National Pain Management Program, Specialty Care Services (10P4E). Key questions were then developed with input from the topic nominator, the ESP coordinating center, the review team, and the technical expert panel (TEP).

The Key Questions were:

1. Compared to usual care, what is the effectiveness of cranial electrical stimulation (CES) for the following conditions: chronic pain, depression, anxiety, PTSD, and insomnia?
2. Compared to usual care, what are the risks of cranial electrical stimulation (CES) for the following conditions: chronic pain, depression, anxiety, PTSD, and insomnia?

The review was registered in PROSPERO: CRD42016023951.

## SEARCH STRATEGY

We searched Cochrane (through 10/10/2017), PsycINFO (through 10/10/2017), and Embase (through 10/10/2017), and PubMed (through 10/10/2017) for relevant literature using key terms relating to the conditions of interest and cranial electrical stimulation intervention. We also searched for similar articles in PubMed through 10/10/2017 for three key publications.^7-9^ The full search strategy is available in Appendix A. In addition to these searches, we also included references from expert recommendations, and searches of manufacturer websites or other material.

## STUDY SELECTION

All titles were screened for retrieved citations by the Principal Investigator. Abstracts were then screened for relevant citations. For those abstracts deemed relevant, full-text articles were retrieved and screened against the following PICOTS framework, which describes our inclusion criteria:

Study design: Only randomized controlled trials were included

Population(s): Adult patients with one or more of the following conditions: a chronic pain condition, depression, anxiety, insomnia, and posttraumatic stress disorder (PTSD)

Intervention(s): Any cranial electrical stimulation (CES) device used in the home setting

Comparator(s): Usual care including appropriate known treatments

Outcome(s): Chronic pain: pain severity, use of opioid analgesic medication, quality of life, and daily functioning; Depression and anxiety: clinical assessments, scores on standardized inventories; PTSD: symptom severity, quality-of-life measures, daily functioning; Insomnia: ability to initiate /maintain sleep, resolution of symptoms

Timing: No restrictions

Setting: Home setting, or office-based if needed for the conduct of the trial. Studies of hospitalized patients were excluded.

## DATA ABSTRACTION

We abstracted data on the following: condition, description of patients, description of CES, description of sham, sample size, duration of treatment, assessment of blinding, and results. Many studies reported outcomes in multiple domains. We only extracted primary outcomes. In other words, if the study assessed patients with a painful condition, we extracted pain outcomes. If the study assessed patients with anxiety, we extracted anxiety outcomes, etcetera.

## QUALITY ASSESSMENT

We assessed all included randomized controlled trials with the Cochrane Risk of Bias tool.^10^ Each included study was ranked Low, Unclear, or High (green, yellow, and red, respectively) on seven domains: random sequence generation, allocation concealment, blinding of participants and personnel, blinding of outcome assessment, incomplete outcome data, selective reporting, and other sources of bias. A full description of these domains is available in Appendix B. We judged that blinding was Low risk of bias only if a quantitative assessment was made of the blinding and similar proportions of subjects in each group believed they received active CES. We assessed risk of bias for the outcome assessment made nearest the end of the CES treatment.

## DATA SYNTHESIS

For continuous outcomes, sample size, mean change, and its standard deviation were extracted for each CES group and comparator group within each trial. If the mean change was not reported for a trial, then data at baseline and follow-up were extracted and a mean change was estimated. To estimate the standard deviation of the mean change, both the baseline and follow-up standard deviations were used and adjusted for the dependence between the two by using a correlation of 0.5 (the midpoint). A standardized mean difference (SMD) and its 95% confidence interval (CI) were estimated comparing the mean change between the CES and comparator group. A SMD less than zero suggests that the CES group performed better than the comparator group. For binary data, the sample size, number or percent of patients with an event were extracted. A risk ratio (RR) and its 95% CI was estimated comparing the CES group to the comparator group.

A forest plot was created that included all studies with data capable of supporting an effect size analysis to facilitate visual comparison of results across studies and outcomes.

There were too few studies in any category of condition and specific CES device treatment to support meta-analysis. Therefore, our synthesis is narrative.

## RATING THE BODY OF EVIDENCE

Where possible a summary of findings and quality of evidence table was used to summarize the existing evidence. Based on the GRADE working group,^11^ the quality of the evidence was categorized as follows:

High: We are very confident that the true effect lies close to that of the estimate of the effect.

Moderate: We are moderately confident in the effect estimate: The true effect is likely to be close to the estimate of the effect, but there is a possibility that it is substantially different.

Low: Our confidence in the effect estimate is limited: The true effect may be substantially different from the estimate of the effect.

Insufficient: We have very little confidence in the effect estimate: The true effect is likely to be substantially different from the estimate of effect.

GRADE evaluates the quality of the evidence across all identified studies contributing to the outcome of interest.

## PEER REVIEW

A draft version of the report was reviewed by technical experts and clinical leadership. Reviewer comments and our response are documented in Appendix C.