# INTRODUCTION

Cranial electrical stimulation (CES) is a non-invasive method of applying low-intensity electrical current to the head. It is related to but distinct from other forms of transcranial electrical stimulation including electroconvulsive therapy, transcranial direct current stimulation (tDCS), and high-definition transcranial direct current stimulation. The different versions of transcranial electrical stimulation vary in the placement of electrodes, the intensity of the current, and the waveform of the current.^1^ According to Guleyupoglu and colleagues, CES evolved from the concept of “electrosleep,” first investigated at the beginning of the 20th century.^1^ Most of the early research and applications occurred in Russia. Beginning in the 1960s, the concept of electrosleep became more popular in the USA. Because of the belief that the treatment did not actually induce sleep, but rather the sleep was a side effect of the relaxing effect of the current stimulation, the name was changed from “electrosleep” to “cranial electrical stimulation.”^1^ Other proposed names, which have not persisted, included “transcerebral electrotherapy” and “NeuroElectric Therapy.” The latter is noteworthy because it gave its name to an early CES device, the Neurotone 101, which was the first device approved by the FDA.^1^ All subsequent CES devices have been cleared for marketing by FDA based on the concept of claiming equivalency to the Neurotone 101. The status of cranial electrical stimulation devices and FDA regulation remains a matter of some controversy.

After an initial burst of research activity in the 1970s and early 1980s, published research on CES entered a quiescent phase, but then resumed and accelerated beginning about 2005. CES has been proposed as a therapy for anxiety, pain, insomnia, depression, headache, fibromyalgia, and numerous other conditions.^1^ An early meta-analysis by Klawansky and colleagues^2^ identified 8 sham-controlled RCTs for anxiety, two RCTs for brain dysfunction, two trials for headache and two trials for insomnia. Employing an effect size approach, which pooled studies across outcomes and types of CES, the authors found a statistically significant effect size of -0.58 (95% CI -0.95, -0.22) favoring active treatment for the anxiety outcome. Pooled effects for the other conditions showed no benefit for insomnia or brain dysfunction and a small beneficial effect for headache. The authors cautioned, however, that the quality of included studies was “quite low”, due mostly to inadequate blinding. They concluded that larger, more rigorous studies were needed. Regarding the blinding, a more recent Cochrane review of CES in acute uncomplicated depression by Kavirajan and colleagues^3^ restricted their eligibility criteria to RCTs with a convincing sham, diagnosis using standardized criteria, and assessments with validated rating instruments, and reported finding no studies of subjects with depression meeting these criteria.

The most commonly used CES devices in the USA are the Alpha-Stim products and the Fisher-Wallace Cranial Electrical Stimulator.^4^ They differ in the location of the electrodes (ear clips in the former, sponge electrodes at the temples in the latter) and in the amount and type of current. Both are FDA-cleared for marketing for the treatment of anxiety, depression, and insomnia.

One driver for the resurgence in interest in CES has been the Department of Defense and Department of Veterans Affairs authorizing practitioners to prescribe CES for anxiety, post-traumatic stress disorder, insomnia, depression and headache. One survey of active duty service members and veterans reported on the responses from 152 subjects (a 10% response) rate, and found that 99% of respondents believed CES was effective and 99% considered CES to be safe.^5^ Another VA study, that included CES among a number of alternative treatments for Veterans with chronic pain, found a statistically significant decrease of 1.0 points (on a 0-10 point pain rating scale) in a pre/post study.^6^ Anecdotal evidence suggests that the demand for CES devices among Veterans is increasing. This systematic review was requested by VA to review the RCT evidence for effectiveness in these conditions.