# EXECUTIVE SUMMARY

## ABSTRACT

### Background

Cranial electrical stimulation (CES) is increasing in popularity as a treatment, yet of uncertain clinical benefit.

### Purpose

To review evidence about the effectiveness and harms of CES for patients with chronic painful conditions, depression, anxiety, PTSD, and insomnia.

### Data Searches

Searches of multiple databases from inception to 10/10/2017; reference-mining of included articles; recommendations from experts.

### Study Selection

Randomized controlled trials of CES versus usual care or sham CES.

### Data Extraction

Data extraction was performed in duplicate. The Principal Investigator performed the Strength of Evidence assessment.

### Data Synthesis

28 relevant publications from 26 RCTs met eligibility criteria. Two small RCTs compared CES to usual care, neither reported a statistically significant benefit. Four old RCTs and one modern RCT provided low strength evidence of a possible benefit of CES compared to sham in patients with anxiety and depression. RCT results were conflicting for fibromyalgia, headache, other painful conditions, depression and insomnia. There is low strength evidence that CES does not cause serious side effects. All RCTs were judged to be at high risk of bias because of the possibility of unblinding of therapy.

### Limitations

All RCTs were judged to be at high risk of bias; there were too few RCTs of the same patient population and intervention to support statistical pooling.

### Conclusions

The evidence is insufficient to support conclusions that CES has clinically important effects on headache, fibromyalgia, neuromuscular pain, depression, PTSD, or insomnia. There is low-strength evidence for a possible beneficial effect of modest size in patients who have anxiety with depression. CES is probably safe, in that no serious side effects have been reported in RCTs, although reporting bias is present.