# APPENDIX E CITATIONS OF FULL-TEXT EXCLUDES

Barclay, T. H. (2012). The Efficacy of Cranial-electrotherapy Stimulation (CES) Using Alpha-Stim Technology in The Treatment of Anxiety Disorders. Http://clinicaltrials.gov/show/NCT01533415. Retrieved from http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/796/CN-01038796/frame.html
Bystritsky, A., Kerwin, L., & Feusner, J. (2008). A pilot study of cranial electrotherapy stimulation for generalized anxiety disorder. J Clin Psychiatry, 69(3), 412-417.18348596
Capel, I. D., Dorrell, H. M., Spencer, E. P., & Davis, M. W. (2003). The amelioration of the suffering associated with spinal cord injury with subperception transcranial electrical stimulation. Spinal cord, 41(2), 109-117. Retrieved from http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/767/CN-00422767/frame.html doi:10.1038/sj.sc.3101401 12595874
Coursey, R. D., Frankel, B. L., Gaarder, K. R., & Mott, D. E. (1980). A comparison of relaxation techniques with electrosleep therapy for chronic, sleep-onset insomnia a sleep-EEG study. Biofeedback Self Regul, 5(1), 57-73.6989409
Dastjerdi, G., Mirhoseini, H., & Mohammadi, E. (2015). Investigating the synergistic effects of transcranial direct current stimulation and cranial electrical stimulation in treatment of major depression in a double blinded controlled trial. Biomedical and Pharmacology Journal, 8(2), 1267-1274. doi:10.13005/bpj/885
De Felice, E. A. (1997). Cranial electrotherapy stimulation (CES) in the treatment of anxiety and other stress-related disorders: A review of controlled clinical trials. Stress Medicine S2- Stress and Health: Journal of the International Society for the Investigation of Stress, 13(1), 31-42.
Edelmuth, R. C., Nitsche, M. A., Battistella, L., & Fregni, F. (2010). Why do some promising brain-stimulation devices fail the next steps of clinical development? Expert Rev Med Devices, 7(1), 67-97. doi:10.1586/erd.09.64 20021241
Greenblatt, M., Grosser, G. H., & Wechsler, H. (1964). DIFFERENTIAL RESPONSE OF HOSPITALIZED DEPRESSED PATIENTS TO SOMATIC THERAPY. Am J Psychiatry, 120, 935-943. doi:10.1176/ajp.120.10.935 14138843
Guleyupoglu, B., Schestatsky, P., Edwards, D., Fregni, F., & Bikson, M. (2013). Classification of methods in transcranial electrical stimulation (tES) and evolving strategy from historical approaches to contemporary innovations. J Neurosci Methods, 219(2), 297-311. doi:10.1016/j.jneumeth.2013.07.016 23954780
Hare, J. P., Misialek, L. H., Palis, K., & Wong, C. (2016). Using Cranial Electrotherapy Stimulation Therapy to Treat Behavioral Health Symptoms in a Combat Operational Setting. Mil Med, 181(11), 1410-1412. doi:10.7205/milmed-d-16-00019 27849474
Hein, E., Nowak, M., Kiess, O., Biermann, T., Bayerlein, K., Kornhuber, J., & Kraus, T. (2013). Auricular transcutaneous electrical nerve stimulation in depressed patients: a randomized controlled pilot study. Journal of neural transmission (Vienna, Austria : 1996), 120(5), 821-827. Retrieved from http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/011/CN-00967011/frame.html doi:10.1007/s00702-012-0908-6
Kavirajan, H. C., Lueck, K., & Chuang, K. (2014). Alternating current cranial electrotherapy stimulation (CES) for depression. Cochrane Database Syst Rev, 7, Cd010521. doi:10.1002/14651858.CD010521.pub2
Kim, H. J., Kim, W. Y., Lee, Y. S., Chang, M. S., Kim, J. H., & Park, Y. C. (2008). The effect of cranial electrotherapy stimulation on preoperative anxiety and hemodynamic responses. Korean Journal of Anesthesiology, 55(6), 657-661. Retrieved from http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/087/CN-01045087/frame.html
Kirsch, D. L., Price, L. R., Nichols, F., Marksberry, J. A., & Platoni, K. T. (2014). Military service member and veteran self reports of efficacy of cranial electrotherapy stimulation for anxiety, posttraumatic stress disorder, insomnia, and depression. US Army Med Dep J, 46-54.25830798
Kirsch, D. L. G. M. (2007). CES in the Treatment of Depression, Part 2. Practical Pain Management, 7(2), 32-40.
Kirsch, D. L. G. M. (2007). CES in the Treatment of Insomnia: A Review and Meta-analysis. Practical Pain Management, 7(8), 30-43.
Klawansky, S., Yeung, A., Berkey, C., Shah, N., Phan, H., & Chalmers, T. C. (1995). Meta-analysis of randomized controlled trials of cranial electrostimulation. Efficacy in treating selected psychological and physiological conditions. J Nerv Ment Dis, 183(7), 478-484.7623022
Koegler, R. R., Hicks, S. M., & Barger, J. H. (1971). Medical and psychiatric use of electrosleep. Transcerebral electrotherapy. Dis Nerv Syst, 32(2), 100-104.5313321
Lee, S. H., Kim, W. Y., Lee, C. H., Min, T. J., Lee, Y. S., Kim, J. H., & Park, Y. C. (2013). Effects of cranial electrotherapy stimulation on preoperative anxiety, pain and endocrine response. J Int Med Res, 41(6), 1788-1795. doi:10.1177/0300060513500749 24265330
Levitt, E. A., James, N. M., & Flavell, P. (1975). A clinical trial of electrosleep therapy with a psychiatric inpatient sample. Aust N Z J Psychiatry, 9(4), 287-290.769773
Libretto, S., Hilton, L., Gordon, S., & Zhang, W. (2015). Effects of Integrative PTSD Treatment in a Military Health Setting. Energy, 7(2), 33.
Lu Ling, & fJun, H. U. (2014). A Comparative study of anxiety disorders treatment with Paroxetine in combination with cranial electrotherapy stimulation therapy. Medical Innovation of China, 11(8), 80-82.
Lyon, D., Kelly, D., Walter, J., Bear, H., Thacker, L., & Elswick, R. K. (2015). Randomized sham controlled trial of cranial microcurrent stimulation for symptoms of depression, anxiety, pain, fatigue and sleep disturbances in women receiving chemotherapy for early-stage breast cancer. Springerplus, 4, 369. doi:10.1186/s40064-015-1151-z 26435889
Man, S. C., Hung, B. H., Ng, R. M., Yu, X. C., Cheung, H., Fung, M. P., … Zhang, Z. J. (2014). A pilot controlled trial of a combination of dense cranial electroacupuncture stimulation and body acupuncture for post-stroke depression. BMC complementary and alternative medicine, 14, 255. Retrieved from http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/106/CN-01115106/frame.html doi:10.1186/1472-6882-14-255 25038733
Marshall, A. G., & Izard, C. E. (1974). Cerebral electrotherapeutic treatment of depressions. J Consult Clin Psychol, 42(1), 93-97.4814104
Mindes, J., Dubin, M. J., & Altemus, M. (Eds.). (2015). Cranial electrical stimulation. New York, NY: Springer Science + Business Media.
Novakovic, V., Sher, L., Lapidus, K. A., Mindes, J., J, A. G., & Yehuda, R. (2011). Brain stimulation in posttraumatic stress disorder. Eur J Psychotraumatol, 2 doi:10.3402/ejpt.v2i0.5609
O'Connell, N. E., Wand, B. M., Marston, L., Spencer, S., & Desouza, L. H. (2010). Non-invasive brain stimulation techniques for chronic pain. Cochrane Database Syst Rev(9), Cd008208. doi:10.1002/14651858.CD008208.pub2
O'Connell, N. E., Wand, B. M., Marston, L., Spencer, S., & Desouza, L. H. (2011). Non-invasive brain stimulation techniques for chronic pain. A report of a Cochrane systematic review and meta-analysis. Eur J Phys Rehabil Med, 47(2), 309-326.21494222
Overcash, S. J. (1999). Cranial electrotherapy stimulation in patients suffering from acute anxiety disorders. Am J Electromed, 16(1), 49-51.
Passini, F. G., Watson, C. G., & Herder, J. (1976). The effects of cerebral electric therapy (electrosleep) on anxiety, depression, and hostility in psychiatric patients. J Nerv Ment Dis, 163(4), 263-266.972328
Pérez Pichardo, M. F., Freyre Vega, C. A., & Moo Estrella, J. A. (2017). Effects of cranial electric stimulation on the executive functions of patients with insomnia. Brain Stimulation, 10(2), 493. doi:10.1016/j.brs.2017.01.441
Philip, P., Demotes-Mainard, J., Bourgeois, M., & Vincent, J. D. (1991). Efficiency of transcranial electrostimulation on anxiety and insomnia symptoms during a washout period in depressed patients. A double-blind study. Biol Psychiatry, 29(5), 451-456.2018818
Rose, K. M., Taylor, A. G., & Bourguignon, C. (2009). Effects of cranial electrical stimulation on sleep disturbances, depressive symptoms, and caregiving appraisal in spousal caregivers of persons with Alzheimer's disease. Appl Nurs Res, 22(2), 119-125. doi:10.1016/j.apnr.2007.06.001 19427574
Ryan, J. J., & Souheaver, G. T. (1976). Effects of transcerebral electrotherapy (electrosleep) on state anxiety according to suggestibility levels. Biol Psychiatry, 11, 233-237.786380
Schmitt, R., Capo, T., & Boyd, E. (1986). Cranial electrotherapy stimulation as a treatment for anxiety in chemically dependent persons. Alcohol Clin Exp Res, 10(2), 158-160.3521373
Schmitt, R., Capo, T., Frazier, H., & Boren, D. (1984). Cranial electrotherapy stimulation treatment of cognitive brain dysfunction in chemical dependence. J Clin Psychiatry, 45(2), 60-61, 62-63.
Shealy, C., Cady, R. K., Wilkie, R. G., Cox, R., Liss, S., & Clossen, W. (1989). Depression: a diagnostic, neurochemical profile and therapy with cranial electrical stimulation (CES). Journal of Neurological and Orthopaedic Medicine and Surgery, 10(4), 319-321.
Smith, R. B. (1999). Cranial electrotherapy stimulation in the treatment of stress related cognitive dysfunction with an eighteen month follow-up. Journal of Cognitive Rehabilitation S2- Cognitive Rehabilitation, 17(6), 14-18.
Tan, G., Dao, T. K., Smith, D. L., Robinson, A., & Jensen, M. P. (2010). Incorporating complementary and alternative medicine (CAM) therapies to expand psychological services to veterans suffering from chronic pain. Psychological Services, 7(3), 148-161.
Tomsovic, M., & Edwards, R. V. (1973). Cerebral electrotherapy for tension-related symptoms in alcoholics. Q J Stud Alcohol, 34(4), 1352-1355.4588298
Von Richthofen, C. L., & Mellor, C. S. (1980). Electrosleep therapy: a controlled study of its effects in anxiety neurosis. Can J Psychiatry, 25(3), 213-219.7370903
Voris, M. D. (1995). An investigation of the effectiveness of cranial electrotherapy stimulation in the treatment of anxiety disorders among outpatient psychiatric patients, impulse control parolees and pedophiles. Dallas and Corpus Christi, Texas: Delos Mind/Body Institute Newsletter.