# APPENDIX C PEER REVIEW COMMENTS AND AUTHOR RESPONSES

Comments | Response
Page 18: Research gaps/future research: It might be useful to highlight the need for understanding whether possible benefits persist after treatment discontinuation or whether relapse in symptoms occur. In addition, there also is a need for comparative effectiveness research (rather that studies of “usual care” which evolves over time. VA is investing in dissemination of interventions for PTSD, depression and insomnia. An important question is whether CES is comparable to other evidence based treatments. Finally, quality of life outcomes should be incorporated into future research. This may be worthy of mention in this section of the review as well. | We have added these helpful suggestions to the future research section.
The study will be of significant value to providers in Pain Management as we discuss with our patients treatment options. Management of chronic pain is founded on a biopsychosocial model of pain. Treatment is often multimodal. While complementary and non-traditional approaches may have their value as one part of the pain management armamentarium, the many choices available nowadays may appear overwhelming to the medical providers and patients. Thus it is important to guide patients to the treatment options that have good evidence of effectiveness and a favorable benefit versus risk ratio. There are evidence-based pain behavioral pain management options (such as Cognitive Behavioral Therapy for Chronic Pain (CBT-CP), as well as physical therapy and other rehabilitation approaches with proven long-term benefit. It is important that “newer” pain management approaches such as CES do no distract patients from engaging in the therapeutic modalities that have much greater evidence of long term benefit. In regard to long-term risks of CES, the current evidence is rather sparse. While this systematic review indicates low evidence that CES does not cause serious side effects. It remains concerning that the older literature reference cited (reference 23, Feighner et al, 1974) reports “massive worsening of depressive symptoms” from so-called “electrosleep therapy”. We need long-term studies include appropriate measurements of mood and cognitive function, with adequate sensitivity for change of time, in order to conclude that gradual changes in these functions and other adverse effects do not occur over time. | We have added to the future research section the need for long-term studies of safety.
The systematic review does not make recommendations about use of CES in daily practice, and it will be interesting to see whether the information of this review will lead to any policy changes in VHA.
In the reference to the Cochrane review by Kavirajan, page 2 line 44, the author's name is misspelled (should be “Kavirajan”). In addition, the lack of eligible studies in that Cochrane review was not due solely to the lack of trials with credible blinding in the sham group. Rather, some trials were excluded due to failure to use validated diagnostic criteria or rating scales. Additionally, since the review focused on acute major depression, which is the focus of clinical trials of most FDA-approved antidepressant agents, trials examining CES in chronic depression or treatment refractory depression or bipolar depression were excluded. So, the current characterization of the negative findings by Kavirajan et al is somewhat inaccurate. It could be corrected by stating that “a more recent Cochrane review of CES in acute uncomplicated by Kavirajan and colleagues3 restricted their eligibility criteria to RCTs with a convincing sham, diagnosis using standardized criteria, and assessments with validated rating instruments, reported finding no studies meeting these criteria.” | We have made this correction.
The discussion of trials for “anxiety and depression” should state what specific anxiety disorders were examined, as anxiety is a symptom of various anxiety disorders and not a diagnosis in itself. The discussion should note which anxiety disorders were diagnosed using which criteria. In most of the trials considered (other than Barclay et al), it is unclear whether formal diagnostic criteria were used in the inclusion criteria and this should be noted in the text. | We have added text about this. Three of these studies were old (more than 40 years) and as noted by the reviewer, the diagnostic criteria used were either not stated or no longer considered current. Only in the study by Barclay and colleagues were formal modern criteria used (DSM-IV, SCID-I and the HAM-A scale).
Finally, there is a typo on page 2, line 19: “become” should be “became”. | This was fixed.