# APPENDIX A SEARCH STRATEGIES

CRANIAL ELECTRIC STIMULATION – SEARCH METHODOLOGY

________________________________________________________________________________________________________

## DATABASE SEARCHED: PubMed

[underlined: SEARCH STRATEGY #1:]

TIME PERIOD COVERED: from inception to 2/1/2016

LANGUAGE: English

“cranial electrical stimulation”(tiab) OR cranial electric stimulat*(tiab) OR electrotherap*(tiab) OR fisher wallace stimulat*(tiab) OR alpha-stim(tiab)

[underlined: SEARCH STRATEGY #1A (update to Search #1):]

TIME PERIOD COVERED: 1/1/2016-7/12/2017

LANGUAGE: English

“cranial electrotherapy” OR cranial electric stimulat* OR cranial electrical stimulat* OR alpha-stim OR fisher wallace stimulat*

[underlined: SEARCH STRATEGY #2:]

TIME PERIOD COVERED: from inception to 7/12/2017

LANGUAGE: ALL

Electrosleep OR “Transcerebral electrotherapy” OR “Neuroelectric therapy”

[underlined: SEARCH STRATEGY #3:]

TIME PERIOD COVERED: from inception to 7/17/2017

LANGUAGE: English

Similar Article searches on the following articles:

A clinical trial of cranial electrotherapy stimulation for anxiety and comorbid depression Timothy H. Barclay a,n, Raymond D. Barclay b, Journal of Affective Disorders 164 (2014) 171–177 24856571

Alfred G. Bracciano , Wen-Pin Chang , Stephanie Kokesh , Abe Martinez ,Melissa Meier & Kathleen Moore (2012) Cranial Electrotherapy Stimulation in the Treatment of Posttraumatic Stress Disorder: A Pilot Study of Two Military Veterans, Journal of Neurotherapy, 16:1, 60-69, DOI: 10.1080/10874208.2012.650100 – NOT IN PUBMED

Efficacy of cranial electric stimulation for the treatment of insomnia: A randomized pilot study R. Gregory Lande,*, Cynthia Gragnanib Complementary Therapies in Medicine (2013) 21, 8—13 23374200

Cranial electrical stimulation improves symptoms and functional status in individuals with fibromyalgia

Cranial electrical stimulation improves symptoms and functional status in individuals with fibromyalgia Taylor, A. G., Anderson, J. G. Riedel, S. L. Lewis, J. E. Kinser, P. A. Bourguignon, C. Pain Manag Nurs, (2013) 14(4), 327-335 24315255

[underlined: SEARCH STRATEGY #4:]

TIME PERIOD COVERED: from inception to 10/10/17

LANGUAGE: English

“transcranial electrical stimulation”(Title) OR “transcranial electric stimulation”(Title)

________________________________________________________________________________________________________

## DATABASE SEARCHED: PsycINFO

[underlined: SEARCH STRATEGY #1]

TIME PERIOD COVERED: from inception to 2/4/2016

LANGUAGE: English

S1 TI ( “cranial electrotherapy” OR “cranial electric stimulation” OR “cranial electrical stimulation” ) OR SU ( “cranial electrotherapy” OR “cranial electric stimulation” OR “cranial electrical stimulation” ) OR AB ( “cranial electrotherapy” OR “cranial electric stimulation” OR “cranial electrical stimulation” ) OR (SU electrical stimulation AND ( brain OR cranial OR transcranial ))

AND

TI ( pain OR painful OR depression OR depressive OR anxiety OR anxiety disorders(mh) OR post-traumatic stress OR posttraumatic stress OR “post traumatic stress” OR ptsd OR insomnia OR sleep* OR fibromyalgia ) OR SU ( pain OR painful OR depression OR depressive OR anxiety OR anxiety disorders(mh) OR post-traumatic stress OR posttraumatic stress OR “post traumatic stress” OR ptsd OR insomnia OR sleep* OR fibromyalgia ) OR AB (pain OR painful OR depression OR depressive OR anxiety OR anxiety disorders(mh) OR post-traumatic stress OR posttraumatic stress OR “post traumatic stress” OR ptsd OR insomnia OR sleep* OR fibromyalgia)

OR

TI ( “fisher wallace stimulation” OR alpha-stim ) OR SU ( “fisher wallace stimulation” OR alpha-stim ) OR AB ( “fisher wallace stimulation” OR alpha-stim )

[underlined: SEARCH STRATEGY #1A (update to Search #1):]

TIME PERIOD COVERED: 1/1/2016-7/12/2017

LANGUAGE: English

TI ( “cranial electrotherapy” OR “cranial electric stimulation” OR “cranial electrical stimulation” ) OR SU ( “cranial electrotherapy” OR “cranial electric stimulation” OR “cranial electrical stimulation” ) OR AB ( “cranial electrotherapy” OR “cranial electric stimulation” OR “cranial electrical stimulation” ) OR SU (electrical stimulation AND ( brain OR cranial OR transcranial )) OR TI ( “fisher wallace stimulation” OR alpha-stim ) OR SU ( “fisher wallace stimulation” OR alpha-stim ) OR AB ( “fisher wallace stimulation” OR alpha-stim )

AND

TI ( pain OR painful OR depression OR depressive OR anxiety OR post-traumatic stress OR posttraumatic stress OR “post traumatic stress” OR ptsd OR insomnia OR sleep* OR fibromyalgia ) OR SU ( pain OR painful OR depression OR depressive OR anxiety OR post-traumatic stress OR posttraumatic stress OR “post traumatic stress” OR ptsd OR insomnia OR sleep* OR fibromyalgia ) OR AB (pain OR painful OR depression OR depressive OR anxiety OR post-traumatic stress OR posttraumatic stress OR “post traumatic stress” OR ptsd OR insomnia OR sleep* OR fibromyalgia)

[underlined: SEARCH STRATEGY #2:]

TIME PERIOD COVERED: from inception to 7/12/2017

LANGUAGE: ALL

TI (Electrosleep OR “Transcerebral electrotherapy” OR “Neuroelectric therapy”) OR SU((Electrosleep OR “Transcerebral electrotherapy” OR “Neuroelectric therapy”) OR AB ((Electrosleep OR “Transcerebral electrotherapy” OR “Neuroelectric therapy”)

[underlined: SEARCH STRATEGY #3:]

TIME PERIOD COVERED: from inception to 10/10/17

LANGUAGE: English

TI (“transcranial electrical stimulation” OR “transcranial electric stimulation”)

________________________________________________________________________________________________________

## DATABASE SEARCHED: Cochrane databases

[underlined: SEARCH STRATEGY]

TIME PERIOD COVERED: from inception to 2/4/2016

LANGUAGE: English

[underlined: SEARCH STRATEGY #1]

(“cranial electrotherapy” or “cranial electric stimulation” or “cranial electrical stimulation”:ti,ab,kw) OR (electrical stimulation and (brain or cranial or transcranial)):ti,ab,kw OR (“fisher wallace stimulation” or alpha-stim):ti,ab,kw (Word variations have been searched)

AND

pain or painful or depression or depressive or anxiety or anxiety disorders (mh ) or post-traumatic stress or posttraumatic stress or “post traumatic stress” or ptsd or insomnia or sleep* or fibromyalgia:ti,ab,kw (Word variations have been searched)

[underlined: SEARCH STRATEGY #1A (update to Search #1)]

DATABASE SEARCHED: Cochrane CENTRAL

TIME PERIOD COVERED: 1/1/2016-7/12/2017

LANGUAGE: English

‘“cranial electrotherapy” or “cranial electric stimulation” or “cranial electrical stimulation” in Title, Abstract, Keywords

[underlined: SEARCH STRATEGY #2:]

TIME PERIOD COVERED: from inception to 10/10/17

LANGUAGE: English

“transcranial electrical stimulation” or “transcranial electric stimulation” in Record Title

________________________________________________________________________________________________________

## DATABASE SEARCHED: Embase

[underlined: SEARCH STRATEGY #1:]

TIME PERIOD COVERED: From inception to 7/12/2017

LANGUAGE: English

‘cranial electrotherapy’ OR ‘cranial electric stimulation’ OR ‘cranial electrical stimulation’ OR ‘fisher wallace stimulation’ OR ‘alpha stim’/exp OR ‘alpha stim’

AND

(humans)/lim

[underlined: SEARCH STRATEGY #2:]

TIME PERIOD COVERED: from inception to 7/12/2017

LANGUAGE: ALL

‘electrosleep’/exp OR electrosleep OR ‘transcerebral electrotherapy’ OR ‘neuroelectric therapy’

AND

(humans)/lim

[underlined: SEARCH STRATEGY #3:]

TIME PERIOD COVERED: from inception to 10/10/17

LANGUAGE: English

‘transcranial electrical stimulation’:ti OR ‘transcranial electric stimulation’:ti

________________________________________________________________________________________________________

NOTE: ADDITIONAL FILTERS FOR ANIMAL-ONLY STUDIES WERE APPLIED IN ENDNOTE