# REFERENCES

1 Dijxhoorn DN, Mortier M, van den Berg MGA, Wanten GJA. The Currently Available Literature on Inpatient Foodservices: Systematic Review and Critical Appraisal. J Acad Nutr Diet. Jul 2019;119(7):1118–1141.e36. doi:10.1016/j.jand.2019.01.018 31031106
2 Wall BT, van Loon LJ. Nutritional strategies to attenuate muscle disuse atrophy. Nutr Rev. Apr 2013;71(4):195–208. doi:10.1111/nure.12019 23550781
3 Reber E, Gomes F, Bally L, Schuetz P, Stanga Z. Nutritional Management of Medical Inpatients. J Clin Med. Jul 30 2019;8(8)doi:10.3390/jcm8081130
4 Dutch Malnutrition Steering Group. The Dutch Approach on Malnutrition. [website] Available at: https://www.fightmalnutrition.eu/. Accessed September 28, 2022.
5 Citty SW, Chew M, Hiller LD, Maria LA. Enteral nutrition: An underappreciated source of patient safety events. Nutr Clin Pract. Aug 2024;39(4):784–799. doi:10.1002/ncp.11153 38667904
6 Ethington S, Volpe A, Guenter P, Simmons D. The lingering safety menace: A 10-year review of enteral misconnection adverse events and narrative review. Nutr Clin Pract. Oct 2024;39(5):1251–1258. doi:10.1002/ncp.11191 39023510
7 Joosub I, Emara Z, Eltantawi M, Alzeiby T, Khateery O, Khalil S. Selecting an Automated Parenteral Nutrition Compounder Device at a Tertiary Care Institute in Saudi Arabia. Hosp Pharm. 2021;56(6):760–764.34732935
8 MacKenzie-Shalders K, Maunder K, So D, Norris R, McCray S. Impact of electronic bedside meal ordering systems on dietary intake, patient satisfaction, plate waste and costs: A systematic literature review. Systematic Review. Nutr Diet. 2020;77(1):103–111.31957199
9 Hong JY, Ivory CH, VanHouten CB, Simpson CL, Novak LL. Disappearing expertise in clinical automation: Barcode medication administration and nurse autonomy. J Am Med Inform Assoc. Feb 15 2021;28(2):232–238. doi:10.1093/jamia/ocaa135 32909610
10 Novak LL, Holden RJ, Anders SH, Hong JY, Karsh BT. Using a sociotechnical framework to understand adaptations in health IT implementation. Int J Med Inform. Dec 2013;82(12):e331–44. doi:10.1016/j.ijmedinf.2013.01.009 23562140
11 Bates DW, Cohen M, Leape LL, Overhage JM, Shabot MM, Sheridan T. Reducing the frequency of errors in medicine using information technology. J Am Med Inform Assoc. Jul-Aug 2001;8(4):299–308. doi:10.1136/jamia.2001.0080299 11418536
12 Food and Drug Administration. Guidance for Industry: Bar Code Label Requirements Questions and Answers. Available at: https://www.fda.gov/files/vaccines%2C%20blood%20%26%20biologics/published/Guidance-for-Industry--Bar-Code-Label-Requirements.pdf. Accessed September 27, 2022
13 Wideman MV, Whittler ME, Anderson TM. Barcode Medication Administration: Lessons Learned from an Intensive Care Unit Implementation. In: Henriksen K, Battles JB, Marks ES, Lewin DI, eds. Advances in Patient Safety: From Research to Implementation (Volume 3: Implementation Issues). Agency for Healthcare Research and Quality (US); 2005.
14 Ash JS, Sittig DF, Campbell E, Guappone K, Dykstra RH. An unintended consequence of CPOE implementation: shifts in power, control, and autonomy. AMIA Annu Symp Proc. 2006;2006:11–5.17238293
15 Kaushal R, Shojania KG, Bates DW. Effects of computerized physician order entry and clinical decision support systems on medication safety: a systematic review. Arch Intern Med. Jun 23 2003;163(12):1409–16. doi:10.1001/archinte.163.12.1409 12824090
16 King WJ, Paice N, Rangrej J, Forestell GJ, Swartz R. The effect of computerized physician order entry on medication errors and adverse drug events in pediatric inpatients. Pediatrics. Sep 2003;112(3 Pt 1):506–9. doi:10.1542/peds.112.3.506 12949274
17 Kuperman GJ, Gibson RF. Computer physician order entry: benefits, costs, and issues. Ann Intern Med. Jul 1 2003;139(1):31–9. doi:10.7326/0003-4819-139-1-200307010-00010 12834316
18 Potts AL, Barr FE, Gregory DF, Wright L, Patel NR. Computerized physician order entry and medication errors in a pediatric critical care unit. Pediatrics. Jan 2004;113(1 Pt 1):59–63. doi:10.1542/peds.113.1.59 14702449
19 Aarts J, Ash J, Berg M. Extending the understanding of computerized physician order entry: implications for professional collaboration, workflow and quality of care. Int J Med Inform. Jun 2007;76 Suppl 1:S4–13. doi:10.1016/j.ijmedinf.2006.05.009 16798068
20 Han YY, Carcillo JA, Venkataraman ST, Unexpected increased mortality after implementation of a commercially sold computerized physician order entry system. Pediatrics. Dec 2005;116(6):1506–12. doi:10.1542/peds.2005-1287 16322178
21 Koppel R, Wetterneck T, Telles JL, Karsh BT. Workarounds to barcode medication administration systems: their occurrences, causes, and threats to patient safety. J Am Med Inform Assoc. Jul-Aug 2008;15(4):408–23. doi:10.1197/jamia.M2616 18436903
22 Aarts J, Berg M. Same systems, different outcomes--comparing the implementation of computerized physician order entry in two Dutch hospitals. Methods Inf Med. 2006;45(1):53–61.16482371
23 Novak LL, Anders S, Gadd CS, Lorenzi NM. Mediation of adoption and use: a key strategy for mitigating unintended consequences of health IT implementation. J Am Med Inform Assoc. 2012 2012;19(6):1043–1049. doi:10.1136/amiajnl-2011-000575 22634157
24 Patterson ES, Cook RI, Render ML. Improving patient safety by identifying side effects from introducing bar coding in medication administration. J Am Med Inform Assoc. Sep-Oct 2002;9(5):540–53. doi:10.1197/jamia.m1061 12223506
25 Nundy S, Cooper LA, Mate KS. The Quintuple Aim for Health Care Improvement: A New Imperative to Advance Health Equity. JAMA. Feb 8 2022;327(6):521–522. doi:10.1001/jama.2021.25181 35061006
26 Institute for Safe Medication Practices. Use barcode scanning to prevent errors with enteral nutrition feedings. ISMP Medication Safety Alert! Acute Care. 2024;29(16):1–5.
27 Tyler R, Barrocas A, Guenter P, Value of Nutrition Support Therapy: Impact on Clinical and Economic Outcomes in the United States. JPEN J Parenter Enteral Nutr. Mar 2020;44(3):395–406. doi:10.1002/jpen.1768 31994761
28 Kight CE, Bouche JM, Curry A, Consensus Recommendations for Optimizing Electronic Health Records for Nutrition Care. Article. J Acad Nutr Diet. 2020;120(7):1227–1237. doi:10.1016/j.jand.2019.07.018 31685413
29 Joint Commission. Hospital national patient safety goals 2021. https://www.jointcommission.org/-/media/tjc/documents/standards/national-patient-safety-goals/2021/simplified-2021-hap-npsggoals-final-11420.pdf
30 Cooke A, Smith D, Booth A. Beyond PICO: the SPIDER tool for qualitative evidence synthesis. Qual Health Res. Oct 2012;22(10):1435–43. doi:10.1177/1049732312452938 22829486
31 McGowan J, Sampson M, Salzwedel DM, Cogo E, Foerster V, Lefebvre C. PRESS Peer Review of Electronic Search Strategies: 2015 Guideline Statement. J Clin Epidemiol. Jul 2016;75:40–6. doi:10.1016/j.jclinepi.2016.01.021 27005575
32 Cochrane Methods Bias. Risk Of Bias In Non-Randomized Studies - of Interventions (ROBINS-I). https://methods.cochrane.org/bias/risk-bias-non-randomized-studies-interventions
33 Cochrane Methods Bias. RoB 2: A revised Cochrane risk-of-bias tool for randomized trials. https://methods.cochrane.org/bias/risk-bias-non-randomized-studies-interventions
34 NIH. Study Quality Assessment Tools. https://www.nhlbi.nih.gov/health-topics/study-quality-assessment-tools
35 Viechtbauer W. Conducting Meta-Analyses in R with the metafor Package. Journal of Statistical Software. 08/05 2010;36(3):1 – 48. doi:10.18637/jss.v036.i03
36 Balshem H, Helfand M, Schünemann HJ, GRADE guidelines: 3. Rating the quality of evidence. J Clin Epidemiol. Apr 2011;64(4):401–6. doi:10.1016/j.jclinepi.2010.07.015 21208779
37 Hamilton AB, Finley EP. Qualitative methods in implementation research: An introduction. Psychiatry Res. Oct 2019;280:112516. doi:10.1016/j.psychres.2019.112516 31437661
38 Averill JB. Matrix analysis as a complementary analytic strategy in qualitative inquiry. Qual Health Res. Jul 2002;12(6):855–66. doi:10.1177/104973230201200611 12109729
39 Alrifai MW, Mulherin DP, Weinberg ST, Wang L, Lehmann CU. Parenteral Protein Decision Support System Improves Protein Delivery in Preterm Infants: A Randomized Clinical Trial. Randomized Controlled Trial Research Support, N.I.H., Extramural. JPEN J Parenter Enteral Nutr. 2018;42(1):219–224.29505147
40 Shliakhtsitsava K, Fisher ES, Trovillion EM, Improving vitamin D testing and supplementation in children with newly diagnosed cancer: A quality improvement initiative at Rady Children's Hospital San Diego. Research Support, N.I.H., Extramural. Pediatr Blood Cancer. 2021;68(11):e29217.34286891
41 Ziemba KJ, Kumar R, Nuss K, Estrada M, Lin A, Ayad O. Clinical Decision Support Tools and a Standardized Order Set Enhances Early Enteral Nutrition in Critically Ill Children. Nutr Clin Pract. 2019;34(6):916–921.30932259
42 Citty SW, Kamel A, Garvan C, Marlowe L, Westhoff L. Optimizing the electronic health record to standardize administration and documentation of nutritional supplements. BMJ Quality Improvement Reports. 2017;6(1)
43 De Rueda Félix G, Almendral Vicente A, Eugenia TSM, Mar GSM. Results in the parenteral nutritions electronic prescription following implementation of a computer program. Cost analysis and prescription. Article. Ars Pharmaceutica. 2015;56(2):115–120.
44 Meehan A, Loose C, Bell J, Partridge J, Nelson J, Goates S. Health System Quality Improvement: Impact of Prompt Nutrition Care on Patient Outcomes and Health Care Costs. J Nurs Care Qual. 2016;31(3):217–23.26910129
45 Steele C, Bixby C. Barcode scanning of human milk and enteral formulas improves efficiency and patient safety: A 7-year review. Nutr Clin Pract. 2021;01:01.
46 MacKay M, Anderson C, Boehme S, Cash J, Zobell J. Frequency and Severity of Parenteral Nutrition Medication Errors at a Large Children's Hospital After Implementation of Electronic Ordering and Compounding. Nutr Clin Pract. 2016;31(2):195–206.26214511
47 Skouroliakou M, Konstantinou D, Papasarantopoulos P, Matthaiou C. Computer assisted total parenteral nutrition for pre-term and sick term neonates. Pharm World Sci. 2005;27(4):305–10.16228629
48 Franco KA, O'Mara K. Impact of Computerized Provider Order Entry on Total Parenteral Nutrition in the Neonatal Intensive Care Unit. The Journal of Pediatric Pharmacology & Therapeutics. 2016;21(4):339–345.27713674
49 Huston RK, Markell AM, McCulley EA, Marcus MJ, Cohen HS. Computer programming: quality and safety for neonatal parenteral nutrition orders. Evaluation Study. Nutr Clin Pract. 2013;28(4):515–21.23753649
50 Crews J, Rueda-de-Leon E, Remus D, Sayles R, Mateus J, Shakeel F. Total Parenteral Nutrition Standardization and Electronic Ordering to Reduce Errors: a Quality Improvement Initiative. Pediatric Quality & Safety. 2018;3(4):e093.30229203
51 Kamel AY, Rosenthal MD, Citty SW, Enteral Nutrition Administration Record Prescribing Process Using Computerized Order Entry: A New Paradigm and Opportunities to Improve Outcomes in Critically Ill Patients. JPEN J Parenter Enteral Nutr. 2021;45(3):507–517.32384191
52 Zhang Y, Xu S, Sun C, Dumont H, Han BP. A new set of highly efficient primers for COI amplification in rotifers. Mitochondrial DNA Part B, Resources. 2021;6(2):636–640.33659709
53 Ferguson M, Capra S, Bauer J, Banks M. Development of a valid and reliable malnutrition screening tool for adult acute hospital patients. Nutrition. Jun 1999;15(6):458–64. doi:10.1016/s0899-9007(99)00084-2 10378201
54 Rochow N, Fusch G, Muhlinghaus A, A nutritional program to improve outcome of very low birth weight infants. Clin Nutr. 2012;31(1):124–31.21890250
55 Eleni-dit-Trolli S, Kermorvant-Duchemin E, Huon C, Early individualised parenteral nutrition for preterm infants. Archives of Disease in Childhood Fetal & Neonatal Edition. 2009;94(2):F152–3.18838470
56 Oczujda M, Miechowicz I, Szymankiewicz-Breborowicz M, Czech-Szczapa B, Johnson MJ, Szczapa T. Impact of Computer Calculation Program on Quality of Individualized Parenteral Nutrition and Selected Clinical Parameters of Extremely Low-Birth-Weight Infants. JPEN J Parenter Enteral Nutr. 2021;45(6):1197–1203.33021740
57 Sriram K, Sulo S, VanDerBosch G, A Comprehensive Nutrition-Focused Quality Improvement Program Reduces 30-Day Readmissions and Length of Stay in Hospitalized Patients. Observational Study Research Support, Non-U.S. Gov't. JPEN J Parenter Enteral Nutr. 2017;41(3):384–391.
58 Bierman SM, Peterson SJ, Chen Y. Identification, Coding, and Reimbursement of Pediatric Malnutrition at an Urban Academic Medical Center. Nutr Clin Pract. 2018;33(5):640–646.29532508
59 Institute of Medicine Committee on Quality of Health Care in A. In: Kohn LT, Corrigan JM, Donaldson MS, eds. To Err is Human: Building a Safer Health System. National Academies Press (US). Copyright 2000 by the National Academy of Sciences. All rights reserved.; 2000.
60 Drennan JC, Sheehan TO, Schroeder T, Haller JT. Implementation of a Nurse-Initiated Protocol to Improve Enteral Medication Administration Documentation in Stroke Patients. J Neurosci Nurs. Dec 1 2024;56(6):214–218. doi:10.1097/JNN.0000000000000785 39231433
61 Chew MM, Rivas S, Chesser M, Improving Administration and Documentation of Enteral Nutrition Support Therapy in a Veteran Affairs Health Care System: Use of Medication Administration Record and Bar Code Scanning Technology. J Patient Saf. Jan 1 2023;19(1):23–28. doi:10.1097/PTS.0000000000001076 36538338
62 North JC, Jordan KC, Metos J, Hurdle JF. Nutrition Informatics Applications in Clinical Practice: a Systematic Review. AMIA Annual Symposium Proceedings/AMIA Symposium. 2015;2015:963–72.26958233
63 Steele C, Bixby C. Centralized breastmilk handling and bar code scanning improve safety and reduce breastmilk administration errors. Breastfeed Med. Nov 2014;9(9):426–9. doi:10.1089/bfm.2014.0077 25243824
64 Citty SW, Bjarnadottir RI, Marlowe BL, Nutrition Support Therapies on the Medication Administration Record: Impacts on Staff Perception of Nutrition Care. Nutr Clin Pract. 2021;36(3):629–638.33095472
65 Guenter P, Blackmer A, Malone A, Update on use of enteral and parenteral nutrition in hospitalized patients with a diagnosis of malnutrition in the United States. Nutr Clin Pract. Feb 2022;37(1):94–101. doi:10.1002/ncp.10827 35025121
66 Bauer JC, John E, Wood CL, Plass D, Richardson D. Data Entry Automation Improves Cost, Quality, Performance, and Job Satisfaction in a Hospital Nursing Unit. J Nurs Adm. Jan 2020;50(1):34–39. doi:10.1097/NNA.0000000000000836 31804410
67 Coyle GA, Heinen M. Evolution of BCMA within the Department of Veterans Affairs. Nurs Adm Q. Jan-Mar 2005;29(1):32–8. doi:10.1097/00006216-200501000-00007 15779703