# ACKNOWLEDGMENTS

This work was partially supported by the Durham Center of Innovation to Accelerate Discovery and Practice Transformation (ADAPT) (CIN 13–410) at the Durham VA Health Care System. The authors are grateful to Liz Wing and Dr. Stacy Lavin for their editorial and citation management support and to the following individuals for their contributions to this project:

## Operational Partners

Operational partners are system-level stakeholders who help ensure relevance of the review topic to the VA, contribute to the development of and approve final project scope and timeframe for completion, provide feedback on the draft report, and provide consultation on strategies for dissemination of the report to the field and relevant groups.

- Julie Kurtz MS, RD, CDE
  Chief, Nutrition, Hospitality, & Food Service Chair
  Clinical Nutrition Committee (CNC)
- Dana Lukens, RDN
  Food Service Systems Manager, Co-Chair of Nutrition Informatics
  VA San Diego Healthcare System
- Nicole Steinlage, RD, LD
  Vice Chair
  Marketing and Nutrition Informatics Subcommittee
  Nutrition Field Advisory Board Co-Chair
  NFS Informatics Consulting Work Group

## Technical Expert Panel

To ensure robust, scientifically relevant work, the technical expert panel (TEP) guides topic refinement; provides input on key questions and eligibility criteria, advising on substantive issues or possibly overlooked areas of research; assures VA relevance; and provides feedback on work in progress. TEP members included:

- Sandra Citty, PhD, APRN-BC, CNE, FASPEN
  Clinical Associate Professor
  University of Florida College of Nursing
  Clinical Nurse Investigator
  North Florida/South Georgia Veterans Health System Geriatric Research Education Clinical Center
- Mary Chew, MS, RDN
  Registered Dietitian
  Phoenix VA Health Care System
- Roaxana Poskey, MS, RDN, LD, CNSC, FAND
  Advanced Practice Dietitian-Nutrition Support
  Michael E. DeBakey VA Medical Center
- Cheryl Smith, MS, RD, LD
  Clinical Nutrition Section Chief
  Oklahoma City VA Health Care System