# DISCUSSION

A landmark 1999 Institute of Medicine (IOM) report estimated 44,000 to 98,000 Americans die annually from medical errors.^59^ Automating the delivery of nutritional products for patients in the hospital setting may reduce medical errors while increasing successful nutritional support for at-risk populations. Yet it is unknown to what degree automation optimizes key clinical and patient outcomes. Also, it is unknown how hospital staff implementing and delivering nutrition supports experience such automation innovations.

Our systematic review identified 16 relevant studies that assessed the impact of various forms of automating the delivery of nutrition to hospitalized patients (KQ1). We identified no relevant studies for KQ2, exploring qualitative perceptions of hospital staff on nutritional delivery automation. For KQ1, most included studies were uncontrolled before-after studies (N = 11), with no studies rated as low ROB. Most studies were conducted with pediatric populations (N = 11), of which the majority involved infants in neonatal intensive care units. In the identified studies, the most common type of innovation was automating aspects of nutrition orders (ie, CPOE; N = 12), combined with additional features such as decision support tools or automations in compounding nutrition products. Only 5 studies involved interventions that automated some tasks associated with documenting that nutrition products had been delivered and given to patients at the bedside (Figure 4).

Across all three outcome categories, most studies reported improved outcomes associated with the automation innovation (ie, process outcomes, 90.9%; performance outcomes, 100%; patient outcomes, 85.7%). The only exception was patient harm; the three studies reporting this outcome showed no difference in temporary or serious harms before and after automation implementation (see Figure 8). Yet while the overall trend across results was consistent and positive, the COE for prioritized outcomes (ie, delivery errors, ordering errors, provider satisfaction) were all rated as very low. Certainty of evidence ratings were downgraded due to major limitations in the included studies’ designs and high imprecision of estimates, or concerns about directness of the findings from included studies with populations of most interest to the VA (ie, majority infant populations in included studies vs all adults in VA hospital populations).

Figure 8 Outcome Trends by Automated Nutrition Delivery Intervention Type

Notes. ^a^ Dark blue shading indicates the results favored the automation intervention, regardless of statistical significance. Orange shading indicates that an outcome was reported in the study but did not trend towards improvements in the automation intervention condition.

^b^ All 3 studies reporting patient harms showed no difference in harms when comparing assessments before and after automation intervention implementation.

Figure 8 is a heatmap depicting the distribution of intervention types, outcomes categories, and direction of effect regardless of statistical significance across each of the included studies. This figure is described further in the Discussion section as follows: Across all three outcome categories, most studies reported improved outcomes associated with the automation innovation (ie, process outcomes, 90.9%; performance outcomes, 100%; patient outcomes, 85.7%). The only exception was patient harm; the three studies reporting this outcome showed no difference in temporary or serious harms before and after automation implementation.

While we found no published qualitative studies to address KQ2, we conducted our own qualitative inquiry into staff perspectives on, and experiences with, automated nutrition delivery innovations within the VHA. We interviewed 12 VHA employees across 4 VA Health Care Systems who had interacted with, or participated in, attempts to implement an automated nutrition delivery system. Overall, staff expressed a robust rationale for using automated nutrition to both reduce staff workload and improve patient care and safety. While key informants had experience with a variety of automated nutrition delivery innovations, our findings support a core set of common implementation barriers and facilitators. Key VHA informants reported that the following factors made it easier to implement some type of automation of nutritional delivery in VHA hospitals: integration of an intentional planning period, use of a multidisciplinary implementation team, having a culture of innovation at their hospital, visible support of leadership (eg, time to participant in workgroups during regular tour of duty), effectiveness of building off existing VHA structures, and the essential role of a hospital staff member committed to implementing the change (ie, a local site champion).

Findings from our primary qualitative study highlighted both perceived and experienced workload barriers across different hospital staff roles (eg, nutrition, nursing, pharmacy, food service). The primary barriers to implementation centered on reservations within the pharmacy service line about adapting to perceived increases in workload and uncertainty with scope of duties outside of their professional expertise (eg, verifying nutritional orders without appropriate training) prior to implementation. In contrast, most VHA hospital staff informants, including the pharmacy service line, reported minimal impacts to their scope or workload after the start-up phase.

Taken together, the results of the systematic review show a generally consistent trend towards positive outcomes associated with the implementation of some form of automating nutritional support delivery to hospitalized patients. Findings from our qualitative study provide rich complementary contextual evidence of VHA staff with experience in implementing these types of automation innovations. Our findings are consistent with other recently published studies^60^ evaluating automated nutrition delivery within hospitalized patients that also demonstrated improved patient outcomes and reductions in ordering or delivery errors. For example, a recent quality improvement (QI) project at the Phoenix VA Health Care System assessed the impact of adding enteral nutrition orders within the MAR, and using an existing medication barcode system for nutrition administration, documentation, and monitoring.^61^ This uncontrolled before-after study reported improved documentation of enteral nutritional support received by patients. Additionally, of those nutritional supports ordered but not given to patients, nearly all had documented reasons within the MAR (eg, patient refusal, nutritional support unavailable), which provides hospital staff additional information to guide patient care. Lastly, our results are consistent with an older review of nutrition informatics applications which included decision support tools and CPOE applications focused on nutritional supports.^62^ This review also found that nutrition-specific computerized applications can support improvement in patient outcomes and in clinician performance, specifically within the settings of delivery of nutrients, malnutrition rates, weight loss, blood glucose values, provider efficiency, and rates of error.

Findings from our systematic review and primary qualitative study, coupled with recently published studies, characterize several key considerations for automated nutrition delivery implementation. First, implementation of automated nutrition delivery within a hospital setting is a multi-disciplinary effort. Most of the studies of our review were based on reports from QI projects that described multi-disciplinary planning teams. These planning teams focused on mapping automated nutrition delivery impacts on diverse hospital service lines prior to implementation.^50,63,64^ Second, most studies reported on the necessity of robust education and training across hospital service lines prior to implementing automated nutrition delivery innovations. One study detailed an interdisciplinary workgroup to foster collaboration and ongoing education between pharmacy and nutrition staff.^64^ Findings from our primary qualitative study also found a need for early and ongoing training to sustain successful outcomes and support collegial collaboration across staff involved in automated nutrition delivery innovations. Finally, the limited evidence suggests that staff involved with automated nutrition delivery tend to have positive impressions of the impact of these innovations on the care they provide.^40,42,64^ We found similar impressions among VHA staff interviewed for our qualitative study, who also reported that automating nutrition delivery had minimal impacts on workload after the initial start-up phase.

Limitations

Our results should be interpreted with caution due to limitations of the identified literature. Specifically, most studies assessing the impact of automated nutrition delivery were uncontrolled study designs, with only 1 identified randomized trial. Yet, the dearth of randomized controlled studies in this area is unsurprising. For complex interventions delivered at a system level, such as automating the delivery of nutrition supports, it may not be practicable to conduct randomized trials in many settings. A majority of the studies were also rated as having considerable ROB concerns, a key factor in the overall very low COE ratings. Populations explored were of limited applicability to hospitalized Veterans. Nearly 70% of the literature we identified centered on the use of automated nutrition delivery innovations among hospitalized children; it is unclear whether those findings would translate to adult hospitalized patients who may have more control or autonomy over their nutritional consumption. Moreover, no studies reported subgroups by patient characteristics. A more robust exploration of patient subgroups (eg, by age, health status, comorbidities, length of hospital stay) could indicate which group of patients would benefit from more robust innovations that integrate automatic triggers to monitor nutritional support administration.

While we were able to characterize automation features of such nutrition delivery interventions across the nutrition delivery process (Figure 4), literature identified in this review focused mostly on automating ordering tasks; we have considerably fewer studies evaluating the utility of documenting and monitoring administration of nutritional supports at the bedside found in eMAR and BCMA innovations. We also found no published qualitative studies exploring hospitalized staff perceptions and experiences with automated nutrition delivery. We addressed this weakness in extant literature by conducting our own qualitative study, which to our knowledge is the first of its kind.

We are also limited in our ability to draw strong conclusions about which type of automated nutrition delivery innovation works best for what setting or populations due to heterogeneity across included studies. For any one outcome, there were relatively few studies. Moreover, outcomes and interventions varied widely across included studies, limiting our ability to conduct meta-analysis in many instances. We were also unable to provide direct or indirect comparisons between types of automated nutrition delivery innovations and their comparative impacts on patient, process, and performance outcomes due both to high heterogeneity in outcomes and interventions and incomplete data reporting across studies. While not a specific focus of this review, we did note any use of implementation science strategies (eg, implementation facilitation, audit, and feedback) used in the included studies. We found no evidence of their explicit use in facilitating integration of automated nutrition delivery innovations within hospital settings.

## FUTURE RESEARCH

This comprehensive review of the literature identified several gaps in the current evidence that warrant future investigation. To inform future work in this area, we consider the PICO framework (Table 15). This approach considers the population, intervention, comparator, and outcome to identify gaps.

Table 15 Overview of Evidence Gaps

Domain | Evidence Gap/Area for Future Exploration
Population | - Adult hospitalized patients; - Subgroup exploration by key patient populations related to the following:; ○ Age; ○ Comorbidity; ○ Length of hospital stay
Intervention | - Barcode medication administration; - Electronic medication administration record; - Bundle automation process improvement projects with various implementation strategies such as external facilitation, audit and feedback, or training
Comparator | - Head-to-head comparisons of types CPOE modalities, with and without additional features such as clinical decision supports or integrated calculators; - Robust comparative designs including both randomized trials and comparative non-randomized designs meeting Cochrane EPOC standards)
Outcomes | - Rich qualitative explorations of staff experience with automation innovations across diverse service lines (eg, pharmacy, nutrition, nursing, food service); - Robust measures of staff satisfaction; - Patient-level outcomes such as patient satisfaction, length of hospital stay, and hospital readmissions; - Process outcomes, especially delivery errors

Abbreviations. CPOE=computerized provider order entry; EPOC=Effective Practice and Organisation of Care.

## CONCLUSIONS

Food is medicine and many hospitalized patients are at risk of malnutrition during their care. Automating nutritional support delivery offers a way to standardize and document the ordering, administration, and monitoring of essential nutritional supports to hospitalized patients. Without such systems, it is difficult to ascertain if the right nutritional products are getting to the right patient at the right time. Automating nutrition support delivery offers additional benefits, such as potential reductions in hospital staff time in ordering nutritional products. Numerous national professional societies have advocated for innovations to support the provision of nutritional products to hospitalized patients to reduce health care errors and maximize safety and quality. Our review provides evidence to support the positive impacts that automated nutrition delivery innovations may have on both hospital staff and the patients under their care. The VHA implemented BCMA software nationwide in 2000; yet it is unclear how the modernization of the VHA electronic health record may impact local automated nutrition delivery innovation. VHA is in a unique position to advance the science on optimizing the safety, accuracy, and efficiency of inpatient nutrition delivery via automation. ^25,27–29,57,65–67^