# RESULTS

## LITERATURE FLOW DIAGRAM

Figures 2 and 3 summarize the results of the study selection process for KQ1 and KQ2, respectively. A full list of excluded studies is provided in the Appendix.

Figure 2 Literature Flowchart for KQ1: Effectiveness of Automated Nutrition Delivery

Abbreviations. ECD=Organization for Economic Cooperation and Development.

Literature flow diagram summarizing results of study selection process for key question 1.

Figure 3 Literature Flowchart for KQ2: Experiences with Automated Nutrition Delivery

Abbreviations. OECD=Organization for Economic Cooperation and Development.

Literature flow diagram summarizing results of study selection process for key question 2.

## OVERVIEW OF INCLUDED STUDIES

### KQ1

For the KQ1 search (effectiveness of automated nutrition delivery), we identified 3,585 studies through searches of MEDLINE (via Ovid), EMBASE, and CINAHL (via EBSCO) (Figure 2). An additional 3 articles were identified through manually searching and reviewing bibliographies of relevant review articles for a total of 3,588 articles. After removing duplicates, 2,214 articles remained for title and abstract screening. Of these abstracts, 125 articles flowed to full-text review. We then retained 18 studies for data abstraction, of which, 16 were identified as unique studies. They consisted of 1 RCT, 1 controlled before-after study, 11 uncontrolled before-after studies, and 3 cross-sectional studies.

Included KQ1 studies were conducted across North America and Europe (USA, Poland, Spain, and Greece). We identified no studies conducted in the VA; most studies were conducted with pediatric populations (Table 3). The majority of studies included some form of ordering automation (ie, CPOE; N = 12), many of which were combined with additional features such as decision support tools or automations in compounding nutrition supports (Figure 4). Only 5 studies involved interventions that automated some tasks associated with delivery of ordered products, including documenting that nutrition products had been delivered, and administered, to the patient.

Figure 4 Distribution of Automation Features in Interventions Across the Nutrition Delivery Process^a^

Notes. ^a^ Screening and nutritional assessment are grouped with red bars, ordering and verifying bars are in blue, preparation bar is in green, and administration and monitoring bars are grouped together with gold bars. Interventions could encompass multiple aspects of the delivery process.

Figure 4 Figure 4 is a bar graph depicting the number of automation features reported in the literature across the nutrition delivery steps. One automation feature was reported in the nutritional screening step, 2 in the documenting screening step, 5 in the nutritional assessment step, and 0 in the documenting assessment step. There were 11 automation features reported for ordering nutrition and 6 for documenting the ordering, 2 for verifying the ordering and 2 for documenting the verification. There were only 2 features in the administration step but 5 for the documenting the administration. There were 5 features relevant for the step of monitoring administration and 2 for documenting the monitoring. Lastly, 0 automation features were reported for the end of nutrition or documenting the end of the nutrition.

One RCT study was rated as having some concern for risk of bias due to deviations form intended interventions.^39^ Of the observational studies, 5 were rated as moderate ROB, 6 as serious, 1 as critical, and 1 as fair ROB. Sources of bias among the observation studies included bias due to confounding, bias due to selection of participants, deviations of intended interventions, missing outcome data, and selection of reported results. Of the 3 cross-sectional studies, 2 were rated as poor and 1 as fair ROB. Common sources of bias in the cross-sectional studies included inadequate accounting for confounding variables, selection bias, and sample size justification. See Appendix for the ROB figures.

### KQ2

For the KQ2 search (experiences with automated nutrition delivery), we identified 313 studies through searches of MEDLINE (via Ovid), EMBASE, and CINAHL (via EBSCO) (Figure 3). An additional 6 articles were identified through hand searching and reviewing bibliographies of relevant review articles for a total of 319 articles. After removing duplicates, 218 articles remained. After applying inclusion and exclusion criteria to titles and abstracts, 42 articles were screened at the full-text review stage. Of these, none were retained for data abstraction.

Table 3 Profile of Included Studies

Study Characteristic | Characteristic Category (Number of Relevant Studies)
Total Studies | - 16 studies (18 references)
Key Question | - KQ1 (N = 16); - KQ2 (N = 0)
Study Desings | - Randomized controlled trial (N = 1); - Controlled before-after (N = 1); - Uncontrolled before-after (N = 11); - Cross-sectional (N = 3)
Study Year Range | - 2005 to 2021
Population Focus | - Adults only (N = 5); - Children only (N = 10; - Not reported (N = 1)
Enrollment Setting | - NICU (N = 7); - PICU (N = 1); - Pediatric cancer unit (N = 1); - Children’s hospital (N = 2); - Multiple hospital units (N = 3); - Single hospital (N = 1); - Multiple hospitals (N = 1)
Study Location | - USA (N = 11); - Europe (N = 5)
Intervention Categories | - CPOE (N = 6); - CPOE + calculator (N = 3); - CPOE+ decision support (N = 1); - CPOE + compounding (N = 1); - CPOE +decision support+ compounding (N = 1); - MAR (N = 2); - Barcode scanner (N = 1); EMR alerts (N = 1)
Process Outcomes | - Nutrition supports delivered - not documented (N = 4); Nutrition supports delivered and documented (N = 2); Delivery errors (N = 2); - Ordering errors (N = 4)
Performance Outcomes | - Provider satisfaction (N = 2); - Time (N = 4)
Patient Outcomes | - Time to regain birth weight (N = 4); - Calories or nutrients consumed (N = 5); - Length of hospital stay (N = 3); - Hospital readmission (N = 2); - Temporary harms (N = 3); - Serious harms (N = 1); - Deaths (N = 2)
ROBINS I; Risk of Bias | - Low (N = 0); - Moderate (N = 5); - Serious (N = 6); - Critical (N = 1)
NIH Cross-Sectional Tool; Risk of Bias | - Good (N = 0); - Fair (N = 1); - Poor (N = 2)
ROB 2; Risk of Bias | - Low (N = 0); - Some concerns (N = 1); - High (N = 0)

Abbreviations. CPOE=computerized provider order entry; MAR=medication administration record; NICU=neonatal intensive care unit; PICU=pediatric intensive care unit.

## KEY QUESTION 1: EFFECTIVENESS OF AUTOMATED NUTRITION DELIVERY

### Process Outcomes

In total, 11 studies reported on process outcomes associated with the automation of delivering nutrition supports.^40–50^ These studies reported on the following outcomes: nutrition supports delivered (N = 5)^40–44^; ordering errors (N = 4)^47–50^; and delivery errors (N = 2).^45,46^ Consistent with the process map in Figure 1, we synthesized findings by steps in the delivery process, first summarizing interventions that did not include documentation and then summarizing interventions that included documentation.

#### Delivery of Nutrition Supports—Not Documented

Two uncontrolled, single-center before-after studies (1 serious ROB, 1 moderate ROB) examined the delivery of nutrition supports that did not include an automated documentation of receipt or amount provided or consumed.^40,41,43^ The automated delivery systems for nutrition supports described in these 3 studies included an electronic medical record (EMR) alert for vitamin D testing and supplementation,^40^ CPOE with a clinical decision support tool and feeding order set for initiating enteral nutrition upon admission to the pediatric intensive care unit,^41^ and CPOE without a clinical decision support tool for parenteral nutrition.^43^ Two of the studies were conducted in the United States,^40,41^ and 1 was conducted in Spain.^43^

Automating the delivery of nutrition supports resulted in increased delivery and/or earlier initiation of nutrition supplementation in 2 studies.^40,41^ The first study implemented an EMR best practice advisory (BPA) alert for testing and supplementation of vitamin D in children with newly diagnosed cancer and was conducted in a large tertiary academic hospital.^40^ Findings from this study showed 97% (N = 32) of patients had vitamin D testing and 100% (33) received appropriate vitamin D supplementation delivered after automation was initiated compared to the historic control in which 4 of 26 (15%) patients had vitamin D testing and 2 of 26 (8%) received appropriate vitamin D supplementation. This study also used a CDS tool and educational training to improve compliance; however, the decision support tree was provided as a hard copy and not incorporated as part of the automated system.^40^ In the second study, a CPOE with an automated CDS tool and feeding order set was implemented in a pediatric intensive care unit (PICU) to examine changes in initiating enteral nutrition within the first 48 hours of admission.^41^ After implementation of the automated CDS tools and feeding order set, 81% patients started enteral nutrition within the first 48 hours of admission compared to 63% in the historic control (p < 0.01).^41^

The last study found a decrease in nutrition supplementation orders after implementation of a CPOE system without a CDS in a hospital in Spain.^43^ In the year preceding implementation of the automated system, parenteral nutrition was prescribed 3,530 times across 12 clinical management units. Following implementation of the automated delivery system, parenteral nutrition was prescribed 2,622 times across the same units in 12 months.

#### Delivery of Nutrition Supports—Documented

Two uncontrolled, single-center, before-after quality improvement studies examined the automated delivery combined with automated documentation of nutrition supports (Table 4).^42,44^ The automated delivery and documentation system for nutrition supports included the addition of oral nutrition supplementation (ONS) to the medication order sets and documentation of delivery and consumption in the medication administration record (MAR)^42^ and linkage of the ONS order to the MAR for documentation of consumption and delivery during the administered of medication to patients.^44^ Both studies were conducted in the United States, and funding for the studies was from nonprofit and for-profit awards. Both studies reported positive impacts of automating delivery and documentation of administration on and consumption of oral nutrition supplements resulted in increased administration/delivery and consumption of nutrition supplementation.

The nutritional automation delivery and documentation systems varied across the 2 studies. The first study utilized a Plan-Do-Study-Act 4-cycle iterative design to examine the change in documentation of administration and consumption of ONS following the implementation of nutritional automation delivery and documentation systems.^42^ The automated system included adding ONS to the medication order sets and an electronic nutrition administration record tab in the MAR that prompted documentation of administration and provided a direct link to the intake flowsheet. The study was conducted in patients on medical and oncology units in a medium-sized academic health science center hospital. Following the 4 cycles, consumption of ONS documented in the flowsheet increased from 4,675 of 85,930 mL (5%) in November and December 2014 to 11,812 of 56,955 mL (21%) in November and December 2015; the number of unopened and returned ONS was reduced from 76% to 54%; and 100% of ONS ordered in the MAR was documented as given or not given with 41% given and 59% not given. The second quality improvement study investigated the change in adult patients at risk for malnutrition receiving ONS after the implementation of automating the ONS order to link to the MAR to allow nurses to document the delivery, dose, and compliance during medication pass.^44^ In adults aged 18 and older, oral nutrition supplement delivery increased from 6.1% in the second half of 2011 to 8.1% in the second half of 2013 following the implementation (p < 0.01).^44^

Table 4 Impact of Automated Nutrition Innovation on Supports Delivered

Nutrition Supports Delivered, Not Documented
Study Design | Innovation Comparator | Outcome Measure Definition | Results | ROB
Ziemba, 2019^41^; Uncontrolled before-after | Decision support + CPOE; Pre-implementation of intervention | Number with order sets implemented within 48 hours of admission | Decision support + CPOE intervention N = 221 (81%); Comparator N = 236 (63%); p < 0.01 | Serious
Shliakhtsitsava, 2021^40^; Uncontrolled before-after | EMR Alerts; Historical control | Patients with vitamin D testing and receiving appropriate supplementation | EMR alerts intervention 97%; Comparator 8% | Moderate
De Rueda Félix, 2015^43^; Uncontrolled before-after | CPOE only; Pre-implementation of intervention | TPN prescribed in the 12 months before-after implementation of CPOE | CPOE intervention N = 2622; Pre-implementation comparator N = 3530 | Serious
Nutrition Supports Delivered and Documented
Study Design | Innovation Comparator | Outcome Measure Definition | Results | ROB
Citty, 2017^42^; Uncontrolled before-after | MAR; Pre-implementation of intervention | Percent documented as administered (ie, provided to the patient’s bedside) in the ENAR (no baseline data for this outcome because the system did not exist) | MAR intervention 41% | Moderate
Citty, 2017^42^; Uncontrolled before-after | MAR; Pre-implementation of intervention | Proportion of ml of delivered ONS documented as consumed in the intake flowsheet (average over 4 24-hour periods) | MAR intervention 1,812 ml/56,955 ml (21%); Pre-implementation comparator 4,675 ml/85920 ml (5%) | Moderate
Citty, 2017^42^; Uncontrolled before-after | MAR; Pre-implementation of intervention | Proportion of ml of ONS documented as administered (given, not given) with reasons (no baseline data for this outcome because the system did not exist | MAR intervention 100% (documented) 41% (documented as given) | Moderate
Meehan, 2016^44^; Uncontrolled before-after | MAR; Pre-implementation of intervention | Patients receiving ONS | MAR intervention 794/9761 (8.1%); Pre-implementation comparator 613/10106 6.1%; p < 0.01 | Serious

Abbreviations. CPOE=computerized provider order entry; EMR=electronic medical record; MAR=medication administration record; ONS=oral nutrition supplement; TPN=total parenteral nutrition.

#### Ordering Errors

One cross-sectional study (poor ROB )^47^ and 3 uncontrolled, single-center, before-after studies (2 moderate ROB, 1 serious ROB)^48–50^ investigated ordering errors associated with automated nutrition supplementation. The 3 uncontrolled before-after studies used CPOE, and 1 of those studies^49^ utilized an automated parenteral nutrition calculator and ordering system. The cross-sectional study used a form of CPOE, a total parenteral nutrition (TPN) Formulated Automated Assistant, to aid in the ordering of TPN.^47^ Outcomes assessed varied across the studies. Two studies measured TPN ordering error rates,^49,50^ incidence of adjustments by pharmacist,^48^ and manual versus computer TPN formulation calculation errors.^47^ Three studies were conducted in the United States at single-site children’s hospitals,^48–50^ and 1 study was conducted in Greece at a maternity hospital.^47^ All individual studies demonstrated a reduction in ordering errors.

We were able to pool results across 3 studies (Figure 5).^47,48,50^ One study reported errors across 3 categories of birth weight; we were unable to combine these into 1 effect estimate.^49^ Consistent with the individual study estimates, pooled results indicated the implementation of CPOE significantly reduced ordering errors (OR = 0.12; 95% CI [0.06, 0.23]; 95% prediction interval [PI] [0.06, 0.24]).

Figure 5 Effects of Implementing Computerized Provider Order Entry on Nutrition Supplementation Ordering Errors

Abbreviations. PI=95% prediction interval.

Figure 5 is a forest plot depicting the effects of implementing computerized provider order entry on nutritional supplementation ordering errors. The individual odds ratio, event counts, and risk of bias for three studies are shown. The overall odds ratio across the three studies in this category is 0.12 with a 95% confidence interval of 0.06 to 0.23 and a prediction interval of 0.06 to 0.24.

An additional single-center, before-after study conducted at a children’s hospital with a level 1 pediatric trauma center^49^ assessed the impact of a CPOE and computerized neonatal parenteral nutrition (PN) calculator on order errors. Infants were divided into 3 birth weight groups, <1000 g, 1001–1500 g, and >1500 g. After incorporation of the PN calculator and CPOE system, fewer errors were detected in all 3 birthweight groups. The incidence of ordering errors was reduced from 4.6 per 100 in 2007 to 0.1 per 100 following implementation of the parenteral nutrition calculator and CPOE (no significance tests reported).

#### Delivery Errors

Two cross-sectional studies looked at delivery errors associated with automated nutrition supplementation delivery (Table 5).^45,46^ One study measured delivery errors prevented in human and fortified or formula milk when barcode scanning was used,^45^ and 1 study measured errors in parenteral nutrition prescribing, transcribing, compounding, and administration after implementation of automated ordering and compounding.^46^ Both studies were conducted in the United States at similar size single-site children’s hospitals.

The most recent study, published in 2021, analyzed the impact of using a barcode scanner for human milk, fortifier, and formulas on near misses or errors prevented.^45^ Near misses were defined as scans that identified the wrong provider order or record lot number or expired item at the time of feeding preparation and errors were defined as feeding an infant the wrong order, lot number, or expired milk. Over 7 years, use of barcode scanning resulted in identification of 1,226 near misses of delivery of the wrong provider order or record lot number of 1,231 near misses and errors. Four of the five errors of delivering the wrong milk were due to the human milk not being scanned at the bedside, and 1 error was due to not scanning the milk prior to discharge.^45^ Additionally, 2,103 near misses of using expired human milk were identified. As a result of barcode scanning, no errors for delivering expired milk to an infant were made. Over 2 and a half years, barcode scanning resulted in identification of 480 near misses of delivery of the wrong fortifier or formula, and no infant patient received the wrong fortifier or formula.

The older cross-sectional single-site study examined the frequency of parenteral nutrition administration, transcription, and preparation errors 7 years following the use of a CPOE program with clinical decision support and automated compounding device technologies.^46^ A retrospective look at 52,679 parenteral nutrition orders over a 7-year period found 230 of 84,503 medication errors. Of the 230 errors, 219 (95%) were administration errors. The administration errors included rate changes (34%) or lipid adjustments (23%) after parenteral nutrition initiation and medication incompatibilities (13%). There were no parenteral nutrition transcription errors identified. Using the NCC-MERP harm categories, the majority (90.9%) of the errors were in categories A–D and not likely to cause harm, while 21 of 230 errors (9.1%) were in categories E–F and may have caused temporary patient harm. No error led to permanent harm, required life sustaining treatment, or resulted in death.

Table 5 Impact of Automated Nutrition Innovation on Delivery Errors

Study Design | Innovation Comparator | Outcome Measure Definition | Results | ROB
Steele, 2021^45^; Cross-sectional | Barcode scanner; No comparator | Overall errors prevented (wrong infant’s milk) | Barcode scanner intervention 1226/1231 (99%) | Fair
Steele, 2021^45^; Cross-sectional | Barcode scanner; No comparator | Overall errors prevented (expired human milk) | Barcode scanner intervention N = 2103 (100%) | Fair
Steele, 2021^45^; Cross-sectional | Barcode scanner; No comparator | Overall errors prevented (fortifier or formula) | Barcode scanner intervention N = 480 (100%) | Fair
MacKay, 2016^46^; Cross-sectional | CPOE + compounding + decision support; Historical control of national data | Medication errors over the last 7 years | CPOE + compounding + decision support 230/84503 (0.27%); Historical control 74/4730 (1.6%) | Poor

Abbreviations. CPOE=computerized provider order entry.

#### Certainty of Evidence for Prioritized Process Outcomes

We found very low certainty of the evidence for the prioritized process outcomes (ie, supplements delivered, delivery errors, ordering errors). The COE was downgraded for serious risk of bias, indirectness, and very serious imprecision (Table 6).

Table 6 GRADE Ratings for Prioritized Process Outcomes

Outcome | Number of Studies | Findings | Certainty of Evidence (Rationale)
Nutrition supplements delivered (not documented) | 4 observational studies (4,348 patients) | Order sets implemented in the AND group: 81% versus 63% in the comparator group; Patients receiving appropriate supplementation: 97% in the AND group compared to 8% in the comparator group; Supplements returned: 76% in the intervention arm and 54% in the comparator group; Total reduction in supports prescribed: 908 after implementation of the AND system | Very low certainty (downgraded for serious risk of bias, serious indirectness, and very serious imprecision)
Nutrition supports delivered and documented | 2 observational studies (19,978 patients) | Documented as consumed was 21% versus 5% in the comparator group; Patients receiving nutrition was 8.1% versus 6.1% in the comparator group | Very low certainty (downgraded for serious risk of bias, serious indirectness, and very serious imprecision)
Delivery errors | 2 observational studies (886,203 patients) | Range of errors prevented 99% to 100%; Range of errors since AND implementation 0% to 0.27% | Very low certainty (downgraded for serious risk of bias, very serious indirectness, and extremely serious imprecision)
Ordering errors | 4 observational studies (3,663 patients) | Calculation errors were 0 in the AND group and 28 in the comparator group; Orders needing pharmacist adjustment was 5.6% in the AND group and 30.4% in the comparator group; Overall ordering errors were reduced to 0.1 per 100 in the AND group and 4.6 per 100 in the comparator group; Orders needing clarification or reentry was 3.2% in the AND group and 21.9% in the comparator group | Very low certainty (downgraded for serious risk of bias, and very serious indirectness)

Abbreviations. AND=automated nutrition delivery.

### Performance Outcomes

Only 6 studies reported on performance outcomes associated with the automation of delivering nutrition supports.^40–42,44,50,51^ These studies reported on some aspect of hospital staff satisfaction with the intervention (N = 2)^42,52^ or the time savings from automation (N = 4).^41,44,47,50^

#### Staff Satisfaction

Two moderate ROB uncontrolled, single-center before-after studies^40,51^ examined staff satisfaction with tools developed to address vitamin D supplementation in children newly diagnosed with malignancy and malnutrition in hospitalized patients, respectively (Table 7). Both studies were conducted in the United States at tertiary care academic health centers and integrated with pre-existing electronic health records (EHRs).

In the first study,^40^ a multidisciplinary team at a children’s hospital developed an institutional guideline for vitamin D testing, supplementation, and follow-up testing in children with newly diagnosed cancers after previously noting low rates of testing and supplementation for vitamin D deficiency in their patient population. This institutional guideline was included in a clinical decision-making tree and incorporated into pre-existing oncology order sets within the hospital’s EHR, along with an accompanying BPA for patients lacking recent vitamin D testing or a lack of supplementation in patients in whom testing had been performed and for whom it was indicated. Overall, 16 of 24 eligible clinicians filled out a survey with Likert scales related to use of the clinical decision-making tree and BPA after the implementation of the tools. Responses to these surveys were dichotomized for provider satisfaction, with responses of “moderately high” to “high” utility considered positive. Of the 16 respondents, 67% found the decision-making tree to have moderately high to high utility, and 86% found the BPA/automated triggers to have moderately high to high utility. As this survey was conducted post-implementation, no additional statistical analyses were performed on these data (Table 7).

In the second study,^51^ a multidisciplinary team created an electronic nutrition administration record (ENAR) to consolidate and standardize information about enteral nutrition orders and administration from previously disparate sections of the pre-existing CPOE system and EHR and to reduce redundant documentation. This ENAR section was developed within the MAR, given similar nursing documentation processes for both nutrition supplementation and medications, and it was linked to the “intake and output” flow sheet for ease of review by clinicians. Pre- and post-implementation surveys were performed for nursing and assistant nursing staff related to documentation workflows, with additional post-implementation items including items regarding the tool’s effects on overall practice, documentation accuracy, and awareness of nutritional status. Overall, attitudes were significantly more favorable when comparing enteral nutrition practices after MAR implementation to pre-implementation context. For example, nursing staff reported significant changes in their confidence and knowledge of which patients had an order for ONS. Similarly, hospital staff found it very easy to know when and how much ONS was last given versus pre-implementation, very easy to document the type of ONS consumed, and very easy to document the volume of ONS consumed. While nurses and nursing assistants reported slightly higher rates of ease in locating the ONS to give to patients post-implementation, the difference was not statistically significant. In questions that were asked only in the post-implementation survey, 66% of survey respondents agreed or strongly agreed that documenting within the ENAR had a positive effect on their practice (Table 7).

Table 7 Impact of Automated Nutrition Innovation on Hospital Staff Satisfaction

Study Design | Innovation Comparator | Outcome Measure Definition | Results | ROB
Shliakhtsitsava, 2021^40^; Uncontrolled before-after | EMR alerts; Pre-implementation of innovation | “Moderately high” to “High” perceived utility of automated triggers for the AND innovation | EMR alert intervention N = 16 (86%); Pre-implementation comparator; NR | Moderate
Citty, 2017^42^; Uncontrolled before-after; Companion paper: Kamel, 2021^51^ | MAR; Pre-implementation of intervention | Percent of RN and nursing assistants endorsing “very easy” in knowing that their patient had an ONS order | MAR intervention N = 99 (83%); Pre-implementation comparator N = 128 (56%); p = 0.01 | Moderate
Citty, 2017^42^; Uncontrolled before-after; Companion paper: Kamel, 2021^51^ | MAR; Pre-implementation of intervention | Perceived ease of ONS administration and documentation: RN and nursing assistants endorsing “very easy” documenting the ONS product consumed | MAR intervention N = 89 (74%); Pre-implementation comparator N = 102 (45%); p = 0.01 | Moderate
Citty, 2017^42^; Uncontrolled before-after; Companion paper: Kamel, 2021^51^ | MAR; Pre-implementation of intervention | Perceived ease of ONS administration and documentation: RN and nursing assistants endorsing “very easy” knowing when and how much ONS product was last given to their patient | MAR intervention N = 58 (48%); Comparator: N = 38 (17%); p = 0.01 | Moderate
Citty, 2017^42^; Uncontrolled before-after; Companion paper: Kamel, 2021^51^ | MAR; Pre-implementation of intervention | Perceived ease of ONS administration and documentation: RN and nursing assistants endorsing “very easy” to find the ONS sent from dietary to nursing staff to give to patient | MAR intervention N = 72 (60%); Comparator: N = 111 (49%); p = 0.12 | Moderate
Citty, 2017^42^; Uncontrolled before-after; Companion paper: Kamel, 2021^51^ | MAR; Pre-implementation of intervention | Perceived ease of ONS administration and documentation: RN and nursing assistants endorsing “very easy” documenting volume of ONS consumed | MAR intervention N = 73 (63%); Comparator: 110 (49%); p = 0.01 | Moderate
Citty, 2017^42^; Uncontrolled before-after; Companion paper: Kamel, 2021^51^ | MAR; Pre-implementation of intervention | Perceived improvement of ONS administration and documentation: All staff (RN, RD, MD) endorsing “is much improved” in placing and finding ONS orders | MAR intervention 67% | Moderate
Citty, 2017^42^; Uncontrolled before-after; Companion paper: Kamel, 2021^51^ | MAR; Pre-implementation of intervention | Perceived improvement of ONS administration and documentation: All staff (RN, RD, MD) endorsing “is much improved” in administration of ONS | MAR intervention 60% | Moderate
Citty, 2017^42^; Uncontrolled before-after; Companion paper: Kamel, 2021^51^ | MAR; Pre-implementation of intervention | Perceived improvement of ONS administration and documentation: All staff (RN, RD, MD) endorsing “is much improved” in documentation accuracy of ONS | MAR intervention 40% | Moderate
Citty, 2017^42^; Uncontrolled before-after; Companion paper: Kamel, 2021^51^ | MAR; Pre-implementation of intervention | Perceived impact of MAR for ONS administration and documentation: All staff (RN, RD, MD) endorsing “strongly agree/agree” that MAR for ONS has a “positive effect on my own practice” | MAR intervention N = 94 (66%) | Moderate

Abbreviations. CPOE=computerized provider order entry; EMR=electronic medical record; MAR=medication administration record; ONS=oral nutrition supplement; TPN=total parenteral nutrition.

### Certainty of Evidence for Prioritized Performance Outcomes

We rated the COE for the 2 observational studies reporting an increase in hospital staff satisfaction as very low due to serious risk of bias and very serious imprecision (Table 8).

#### Hospital Staff Time

One cross-sectional study (poor ROB)^47^ and 3 uncontrolled, single-center, before-after studies (2 serious ROB; 1 moderate ROB)^41,44,50^ analyzed aspects of the staff time associated with nutrition supplementation. These included 2 studies measuring time for clinician ordering supplementation,^47,50^ 2 examining pharmacist time for calculating and clarifying orders,^47,50^ 1 studying time for TPN preparation,^47^ and 2 documenting time from screening or admission to initiation of nutrition interventions.^41,44^ The cross-sectional study was performed in Europe at an obstetrics and maternity hospital with neonatal care, and the 3 before-after studies were performed in the United States. Two of these latter 3 studies were initiated at children’s hospitals, while the third was at a level 1 trauma center and magnet hospital with adult care wards. Table 9 provides an overview of the impact of automation innovations on time metrics.

Table 8 GRADE Ratings for Prioritized Performance Outcomes

Outcome | Number of Studies | Findings | Certainty of Evidence (Rationale)
Staff satisfaction | 2 observational studies (170 patients) | Providers highly rating the utility of AND: 86%; Providers highly rating ease of AND ranged from 48% to 63% versus 17% to 49% in the comparator group | Very low certainty (downgraded for serious risk of bias, and very serious imprecision)

#### Time Required as Part of Ordering and Processing Nutrition Supplementation

The older European poor ROB cross-sectional study examining clinician, pharmacist, and technologist time^47^ compared time expenditures for 96 patient orders using a CDS system named the “TPN Formulation Automated Assistant” versus their pre-existing method of manual calculations. In all 96 cases, orders were performed using both methods, with a third party measuring the time required. In all 3 comparisons, use of the computerized tool significantly reduced time expenditures. Physician ordering time was reduced from 7.1 minutes (SD 2.5 min) to 1.1 minutes (SD 0.3), pharmacist calculation time was reduced from 4.2 (SD 2.1) minutes to 1.9 (SD 0.3) minutes, and overall time for TPN preparation from 15.4 (SD 4.4) minutes to 5.2 (SD 0.8) minutes (Table 9).

A US-based before-after study^50^ rated as serious ROB analyzed clinician order writing time and pharmacist time to clarify and process those TPN orders as part of a transition from paper TPN orders to electronic ordering through the local EHR. This intervention was paired with the creation of standardized TPN solutions. For the clinician-ordering outcome, the project lead physician randomly audited orders throughout the project on a quarterly basis, while the project lead pharmacist performed similar quarterly audits for the pharmacist processing time outcome. The number of audits performed was not shared in the paper, nor were any statistical analyses performed. In what is reported, clinician order writing time dropped from 3.5 minutes using paper orders to less than 1 minute using the computerized orders by the end of the project, while pharmacist processing time decreased from 10 minutes per paper order to 5 minutes per computerized order by the project’s conclusion.

#### Time to Initiation of Nutrition Supplementation

The other 2 before-after studies^41,44^ looked at time to initiation of nutrition supports and time to achieving goal nutrition supplementation in patients hospitalized in a pediatric intensive care unit (PICU) and general medical wards, respectively (Table 9). The PICU study41 focused on children < 1 year of age with a diagnosis of respiratory distress or insufficiency, creating an enteral nutrition order set and BPA with age-appropriate supports and titration orders for bedside nurses. The BPA was designed to send an alert 18 hours after admission to the PICU for the eligible patients in whom no enteral feeding had been ordered. The authors compared 272 children admitted post-intervention to a historical cohort in the almost 3 years pre-implementation, finding that a higher proportion of children had nutrition initiated within 48 hours of admission post-implementation (221 [81%] post-implementation vs 236 [63%] pre-implementation, p < .01) and that this nutrition was begun 0.4 days sooner (1.3 days post-implementation vs 1.7 days pre-implementation, p < .01).

The study in adult patients on general medical wards^44^ utilized nursing screening with the Malnutrition Screening Tool.^53^ After identifying patients at risk with the screening tool, the intervention empowered nurses to directly order an intervention with ONS through the EHR, rather than the previous workflow of nurses referring for dietician assessment and recommendations forwarded for physician approval. In the post-implementation workflow, the nursing order was integrated into the MAR and simultaneously notified the dietician to evaluate the patient and validate the order. Chart audits were done for 30 random patients retrospectively to create the comparison cohort, with the time required to initiate ONS reduced from 2.3 days pre-implementation to < 1 day.

Table 9 Impact of Automated Nutrition Innovation on Hospital Staff Time

Study Design | Innovation Comparator | Outcome Measure Definition | Results | ROB
Skouroliakou, 2005^47^; Cross-sectional | CPOE + compounder; Pre-implementation of intervention | Mean time physician spent on TPN prescription | Calculator + compounder intervention; Mean 1.1 minutes (SD 0.3); Pre-implementation comparator; Mean 7.1 minutes (SD 2.5); p < .05 | Poor
Skouroliakou, 2005^47^; Cross-sectional | CPOE + compounder; Pre-implementation of intervention | Mean time pharmacist spent on necessary calculations | Calculator + compounder intervention; Mean 1.9 minutes (SD 0.3); Pre-implementation comparator; Mean 4.2 minutes (SD 2.10); p < .05 | Poor
Skouroliakou, 2005^47^; Cross-sectional | CPOE + compounder; Pre-implementation of intervention | Mean time spent on the preparation of a TPN solution | Calculator + compounder intervention; Mean 5.2 minutes (SD 0.8); Pre-implementation comparator; Mean 15.4 minutes (SD 4.4); p < .05 | Poor
Crews, 2018^50^; Uncontrolled before-after | CPOE only; Pre-implementation of intervention | Order writing time for clinicians | CPOE only intervention; Mean 1 minute; Pre-implementation comparator; Mean 3.5 | Serious
Crews, 2018^50^; Uncontrolled before-after | CPOE only; Pre-implementation of intervention | Time for pharmacist error clarification, correction, and processing for custom TPN | CPOE only intervention; Mean 5 minutes; Pre-implementation comparator; Mean 10 minute | Serious
Meehan, 2016^44^; Uncontrolled before-after | MAR; Pre-implementation of intervention | Time from nutrition screening to initiation of nutrition intervention | MAR intervention; Mean < 24 hours; Pre-implementation comparator; Mean 2.3 days | Serious
Ziemba, 2019^41^; Uncontrolled before-after | Decision support + CPOE; Pre-implementation of intervention | Time to initiation of enteral nutrition from time of admission to the PICU | Decision support + CPOE intervention; Median 1.3 days; Pre-implementation comparator; Median 1.7 days; p < .01 | Moderate

Abbreviations. CPOE=computerized provider order entry; MAR=medication administration record; ONS=oral nutrition supplementation.

### Patient-Level Outcomes

In total, 10 studies^39,41,44,46,48,49,54–57^ reported on the prioritized patient-level outcomes associated with the automation of delivering nutritional supports. These studies reported on the following outcomes: time to regain birthweight (N = 4),^54–56,58^ calories or nutrients consumed (N = 5),^41,48,49,55,56^ length of hospital stay (N = 3),^41,44,57^ hospital readmissions (N = 2),^44,57^ and patient harms (N = 4).^44,46,55^ Only time to regain birthweight was able to be meta-analyzed. All other outcomes are narratively synthesized.^41^

#### Time to Regain Birthweight

One US-based randomized controlled trial^39^ and 3 European-based uncontrolled, single-center, before-after studies^54–56^ examined the time it took preterm infants to regain their birthweight. Two of these studies^39,54^ explored CPOE with embedded calculators and the other 2^55,56^ explored CPOE alone. No studies were rated as low risk of bias.

In the RCT rated as some risk of bias, 42 preterm infants who were less than 3 days old and weighing 1500 grams or less were randomized to receive either the Parenteral Protein Calculator (PPC) (N = 19) or standard of care (N = 23). The PPC tool was developed over 4 months by an interprofessional team of clinical informatics, neonatologists, pharmacists, and others at Vanderbilt University Medical Center. The PPC was a CPOE-integrated computerized decision support system that automated the calculations of parenteral protein values based off information in the structured CPOE and subtracting for enteral protein. The CPOE tool populated the parenteral protein value into the protein field at the time of PN ordering. In the usual care control group, providers calculated the parenteral protein dose with protocols available online and quick-access notes placed in provider work areas. The PPC group regained birthweight faster than the control group, but the trend was not statistically significant (9.6 vs 8 days; OR = 0.38; 95% CI [0.14, 1.41]).

The 3 other studies were all uncontrolled before-after studies (2 serious ROB^54,55^; 1 critical ROB^56^) that compared retrospective cohorts of preterm infants before and after implementation of CPOE for preterm infant feeding orders. One study^54^ assessed the impact of CPOE with a calculator and the other 2 studies^55,56^ assessed the impact of a CPOE without an integrated calculator. In total, these studies included 372 preterm infants (study sample size range: 40 to 238). Individually, these 3 studies showed a trend toward faster weight regain in the group of infants admitted to the neonatal units after implementation of the CPOE nutritional system redesign. These studies were deemed to have sufficient conceptual homogeneity to perform quantitative synthesis. Based on meta-analysis of all patients (Figure 6), there was a significant mean difference in days to regain birthweight favoring the CPOE-exposed cohort of infants (MD = -2.75 days; 95% CI [-3.83, -1.67]; 95% PI [-3.83, -1.67]).

Figure 6 Mean Difference in Time to Regain Birthweight Among Infants in Hospital Settings After Implementation of Computerized Provider Order Entry Systems

Abbreviations. PI=95% prediction interval.

Figure 6 is a forest plot depicting the mean difference in time to regain birthweight among infants in the hospital after implementation of computerized provider order entry. The individual mean differences, number per intervention and control arm, and risk of bias for three studies are shown. The MD across the three studies in this category is -2.751 with a 95% confidence interval of -3.830 to -1.673 and a prediction interval of -3.830, -1.673.

#### Nutrition Supports Consumed

A total of 5 uncontrolled before-after studies^41,48,49,55,56^ assessed the impact of automation of nutrition delivery on some metric of calories or macronutrients consumed. Three were US based^41,48,49^ and 2^55,56^ were based in Europe. All were assessing implementation of CPOE, with or without additional elements: CPOE only (N = 3),^48,55,56^ CPOE plus an embedded calculator (N = 1),^49^ and CPOE with an integrated decision support tool (N = 1).^41^ Three of the studies were rated as moderate risk of bias^41,48,49^ and all were conducted in pediatric populations. Populations, interventions, and outcomes were too diverse to conduct meta-analysis.

The 3 studies that assessed the implementation of CPOE only were all conducted in preterm infants. Two^55,56^ focused on some metric of preterm infant energy intake (eg, total energy intake, intake per day, first day of life energy intake); all studies demonstrated a signal for increased energy intake post-implementation of a CPOE (Table 10). The other CPOE-only study^48^ focused on the proportion of preterm infants that achieved goal PN across 3 macronutrients; this study also showed improved goal nutrition outcomes after CPOE implementation. Days to nutrition goal attainment did not differ before (10.8 days) and after (10 days) CPOE implementation.

Two studies assessed CPOE plus some additional components; results were mixed. The first study^41^ assessed CPOE with an embedded decision support tool among critically ill children in a pediatric intensive care unit. After CPOE implementation, significantly more pediatric patients achieved goal enteral nutrition within the first 48 hours after hospital admission. The last study was conducted among infants requiring parenteral nutrition in the first three weeks of life and found no difference in total calories consumed before and after implementation of a CPOE with an integrated calculator among 3 different birthweight categories of infants.^49^

Table 10 Impact of Automated Nutrition Innovation on Nutrition Supports Consumed

Study Design | Intervention Comparator | Outcome Measure Definition | Results | ROB
Franco, 2016^48^; Uncontrolled before-after | CPOE only; Pre-implementation of intervention | Proportion of neonatal patients who achieve goal nutrition on 3 key macronutrients concurrently (ie, amino acids, lipids, glucose infusion rate) | CPOE only intervention N = 12 (25.5%); Pre-implementation comparator N = 2 (4.5%); p = .05 | Moderate
Eleni-dit-Trolli, 2009^55^; Uncontrolled before-after | CPOE only; Pre-implementation of intervention | Cumulative total energy intake (kcal/kg) among preterm infants | CPOE only intervention; Mean: 3308; SD:165; Pre-implementation comparator N = 20; Mean: 2971; SD:344; Mean difference: 337; p = .001 | Serious
Eleni-dit-Trolli, 2009^55^; Uncontrolled before-after | CPOE only; Pre-implementation of intervention | Mean total energy intake per day (g/kg) | CPOE only intervention; Mean: 118; SD: 6; Pre-implementation comparator N = 20; Mean:106; SD: 12; Mean difference: 12; p not reported | Serious
Oczujda, 2021^56^; Uncontrolled before-after | CPOE only; Pre-implementation of intervention | First DOL energy, kcal/kg/d | CPOE only intervention N = 47; Mean: 62.9; SD: 18.1; Pre-implementation comparator N = 47; Mean: 32.2; SD: 8.03; p < .0001 | Serious
Oczujda, 2021^56^; Uncontrolled before-after | CPOE only; Pre-implementation of intervention | 14th DOL energy, kcal/kg/d | CPOE only intervention N = 47; Mean: 102.1; SD: 30.9; Pre-implementation comparator N = 47; Mean: 68.4; SD: 21.6; p < .001 | Serious
Ziemba, 2019^41^; Uncontrolled before-after | Decision support + CPOE; Pre-implementation of intervention | Percentage of children who reached goal EN in the first 48 hours of admission | Decision support + CPOE intervention N = 272 (38%); Pre-implementation comparator N = 337 (18%); p < .01 | Serious
Huston 2013^49^; Uncontrolled before-after | CPOE + calculator; Pre-implementation of intervention | Caloric intake, kcal/kg/d among babies weighing ≤1000 g) | CPOE + calculator intervention N = 26; Mean 88, SD: 9; Pre-implementation comparator N = 22; Mean: 87, SD: 10 | Moderate
Huston 2013^49^; Uncontrolled before-after | CPOE + calculator; Pre-implementation of intervention | Caloric intake, kcal/kg/d among babies weighing (> 1500 g) | CPOE + calculator intervention N = 16; Mean: 94, SD: 8; Pre-implementation comparator N = 27; Mean: 93, SD:11 | Moderate
Huston 2013^49^; Uncontrolled before-after | CPOE + calculator; Pre-implementation of intervention | Caloric intake, kcal/kg/d among babies weighing 1001–1500 g | CPOE + calculator intervention N = 45; Mean 92, SD: 5; Pre-implementation comparator N = 28; Mean: 92, SD: 6 | Moderate

Abbreviations. CPOE=computerized provider order entry.

#### Length of Hospital Stay and Hospital Readmission

One serious ROB controlled before-after study^57^ and 2 uncontrolled before-after studies (1 moderate ROB, 1 serious ROB)^41,44^ assessed the impact of automation of nutrition delivery on patient length of hospital stay. All 3 studies were conducted in the United States and assessed some form of a CPOE.^41^ Sriram (2017) assessed the impact of adding CPOE to a MAR for adults at risk for malnutrition.^57^ Ziemba (2019) compared the PICU implementing of a CPOE with an embedded decision support tool for infants in respiratory distress.^41^ The last study by Meehan (2016) assessed the impact before and after implementation of a MAR with a CPOE among adults at risk for malnutrition on length of hospital stay (Table 11).^44^

Table 11 Impact of Automated Nutrition Innovation on Length of Hospital Stay

Study Design | Intervention Comparator | Outcome Measure Definition | Results | ROB
Sriram, 2017^57^; Controlled before-after | CPOE + MAR; MAR no CPOE | Hospital length of stay (defined by subtracting admission day from discharge day). | CPOE + MAR intervention N = 500; Mean: 5.3 days, SD: 4.5; MAR no CPOE Comparator N = 769; Mean: 5.4 days, SD: 4.8; Relative risk reduction: 11.7% with CPOE vs 10.0% without CPOE; p = .011 | Serious
Ziemba, 2019^41^; Uncontrolled before-after | Decision support + CPOE; Pre-implementation of intervention | Length of stay (LOS) from admission to hospital discharge days | Decision support + CPOE intervention N = 272; Median: 8.7, SD: NR; Pre-implementation comparator N = 375; Median: 8.4, SD: NR | Serious
Meehan, 2016^44^; Uncontrolled before-after | MAR; Pre-implementation of intervention | Length of patient hospital stay (in days) | MAR only intervention; Mean: 4.47 days; SE: 0.05; Pre-implementation comparator; Mean: 4.87 days, SE: 0.05; Mean difference: 0.40 days; p < .01 | Serious

Abbreviations. CPOE=computerized provider order entry; MAR=medication administration record.

Both of the CPOE embedded within a MAR demonstrated a signal in reducing hospital stays while the CPOE with decision support did not. (See Figure 7 for visualization of point estimates.) The 2 MAR studies also assessed the impact of this innovation on 30-day hospital readmissions and found a significant reduction compared to pre-implementation rates (Table 12).

Figure 7 Mean Difference in Days in Hospital in Patients Exposed to Hospital Settings after Implementation of Computerized Provider Order Entry Systems

Notes. ^a^ Missing group-level standard deviations were imputed as means of group-level standard deviations reported by Meehan 2016 and Sriram 2017.

Abbreviations. PI=95% prediction interval.

Figure 7 is a forest plot depicting the mean difference in days in hospital in patients after implementation of computerized provider order entry system. The individual mean differences, number per intervention and control arm, and risk of bias for three studies are shown. No summary estimates are shown.

Table 12 Impact of Automated Nutrition Innovation on Hospital Readmissions

Study Design | Intervention Comparator | Outcome Measure Definition | Results | ROB
Sriram, 2017^57^; Controlled before-after | CPOE + MAR; MAR no CPOE | Unplanned, all-cause 30-day hospital readmission to any of 12 hospitals in the AHC system | CPOE + MAR intervention N = 500 (15.6%); MAR no CPOE comparator N = 769 (16.4%); Relative risk reduction: 22% with COPE vs 18% without CPOE; p = .01 | Serious
Meehan, 2016^44^; Uncontrolled before-after | MAR; Pre-implementation of intervention | Rate of readmission to the hospital within 30 days for those that are nutrition sensitive (percent probability) | MAR only intervention N = 9761 (19.7% post-implementation); Pre-implementation comparator N = 10106 (16.3%); p < .01 | Serious

Abbreviations. CPOE=computerized provider order entry; MAR=medication administration record.

#### Patient-Level Harms

Three studies assessed some form of patient-level harms; all studies assessed some form of CPOE implementation.^41,46,55^ Two US-based studies assessed all-cause mortality and both were conducted among pediatric populations. One poor ROB cross-sectional study^46^ assessed CPOE with automated compounding and decision support at a large children’s hospital and the other was a serious ROB uncontrolled before-after study that assessed CPOE with a decision support aid in the PICU of a large urban hospital. Both reported no death in the cohorts before and after implementation of the CPOE systems (Table 13). The cross-sectional study by MacKay (2016) also reported harms as categorized by the National Coordinating Council for Medication Error Reporting and Prevention (NCC MERP); 21 errors were identified after CPOE implementation and classified as temporary harms. The last study was a serious ROB uncontrolled before-after study of a CPOE only innovation conducted among preterm infants in France.^55^ This study reported that the number of infants with other harms (eg, nosocomial infections, intraventricular hemorrhage) did not differ before and after CPOE implementation.

Table 13 Impact of Automated Nutrition Innovation on Patient-Level Harms

Temporary Patient Harms
Study Design | Intervention Comparator | Outcome Measure Definition | Results | ROB
MacKay, 2016^46^; Cross-sectional | CPOE + compounding + decision support | NCC-MERP harm categories E–F (temporary harm category) over the last 7 years | CPOE + compounding + decision support intervention N = 21 (9.1%) | Poor
Eleni-dit-Trolli, 2009^55^; Uncontrolled before-after | CPOE only; Pre-implementation of intervention | Negative patient health outcomes | NR; author states that numbers similar between groups | Serious
Deaths
Study Design | Intervention Comparator | Outcome Measure Definition | Results | ROB
MacKay, 2016^46^; Cross-sectional | CPOE + compounding + decision support | All-cause mortality | No deaths after implementation | Poor
Ziemba, 2019^41^; Uncontrolled before-after | Decision support + CPOE; Pre-implementation of intervention | All-cause mortality | 0%; N = 272; Comparator; 0%; N = 375 | Serious

Abbreviations. CPOE=computerized provider order entry; NCC MERP=National Coordinating Council for Medication Error Reporting and Prevention.

## KEY QUESTION 2: EXPERIENCES WITH AUTOMATED NUTRITION DELIVERY

No studies were identified that addressed KQ2.

## QUALITATIVE STUDY: VHA STAFF EXPERIENCES AND PERCEPTIONS OF AUTOMATED NUTRITION DELIVERY

### Key Informants

We interviewed 12 VHA employees across 4 VA Health Care Systems who had interacted with or participated in implementation attempts of an automated nutrition delivery system. Past and present relevant roles of these participants included staff from pharmacy, nutrition, informatics, research, nursing, and clinical providers. We also had representation from leadership in these areas: pharmacy, nutrition, food service, informatics, and nursing. Our sample spanned a cross-section of staff involved with AND whose roles were largely interdisciplinary in nature. Several key informants had multiple job roles and capacities in implementing AND within the VA health care system, leading to more than 12 job titles. (See Appendix for more information of key informant roles.)

### Results of the Qualitative Analysis

#### Making the Case: Why Automate Nutrition Supports?

All participants described significant gaps in documentation, care delivery, and patient safety metrics in the absence of automation of nutrition supports. The theme of a lack of information and communication flowed through all interviews when describing nutrition delivery without having an automation innovation in place. Prior to the implementation of nutrition support automation innovations, key informants often described inconsistent, incomplete documentation of delivery and administration of nutrition orders. Nutritionists and other providers reported that there was no systematic way of knowing if a nutrition intervention was received by the intended patient, whether there was documentation regarding barriers to administration (eg, patient intolerance), or the outcomes of that nutrition intervention. Without automation, paper nutrition charts were the standard; these were not easily accessible to staff on the hospital floors.

The lack of integration of delivery of nutrition support added burden to the staff workload. Informants described seeing nutrition products “piling up” at the nursing desks or being pushed to inappropriate storage locations. Staff morale was also impacted by a lack of information about the nutritional regimes needed by specific patients under their care. Further, some informants described information gaps in nutrition supplementation orders as a potential source of conflict between those who order nutrition products (nutrition service line) and those responsible for administering nutrition products (nursing service line). One nutritionist informant shared:

“It was very frustrating to me to not be able to get the protein supports I had ordered to my patients. I would order it in the electronic record and I was never sure if the intervention was completed by the nursing staff. There was no sign in the medical record. And I could see evidence that it wasn't, because when I went onto the wards, the [nutrition supplement] products were piling up. I started to wonder why I'm even here if I can't make this happen. I started showing up on the unit so I could see what was happening. It just wasn't possible to change anything on that level. The nurses were frustrated too. There are no reminders and no clear indication what to do with the stock that's piling up on their desks. We began collaborating on ideas to solve the problem. I needed to better understand their workflow issues. They suggested BCMA [barcode medication administration].”

Staff also expressed that the lack of automation also impacted patient care and patient safety. Without any automation of the delivery of nutrition interventions, the “6 rights protocol” of right person, product, dose, timing, route, and documentation could not be verified nor documented. There were no safety checks, no accountability processes, and no reliable way to investigate potential nutrition-related safety events (ie, undocumented error of omission). Nearly all staff informants mentioned increasing patient safety as a key driver in the need for automation among hospitalized patients in the VHA.

#### Implementation Facilitators and Barriers: What Helps or Hinders the Implementation of Automation of Nutrition Delivery?

The implementation of AND varied by site. Yet most sites articulated common facilitators and barriers to implementing the innovation.

##### Facilitators of Implementation

Main implementation facilitators were an intentional planning period, multidisciplinary implementation team, a culture of innovation, building off existing VHA structures, and the importance of a local champion for the automation of nutrition support delivery. Development of a multidisciplinary planning team was described as a key factor in the successful implementation. In a VHA that implemented a BCMA, informants described a multidisciplinary workgroup that was convened to plan, implement, and maintain the innovation at their site. Workgroup members included nutrition, food service, pharmacy, information technology, and nursing. Participants on the implementation team reflected on the process as being “rewarding to collaborate with a team committed to patient health and innovation.” Informants identified several key drivers of a rewarding team effort to implementation automation of nutrition support delivery: collaborative group spirit, collegial nature of the group, creative problem solving (eg, supply chain issues, addressing storage limitations, coordinating workflows). They noted the importance of the culture of innovation at their health care site, particularly the strong visible support of leadership (eg, verbal encouragement, time to participant in workgroups during regular tour of duty). Several informants mentioned the key role of having a local champion to support and spearhead progress. Finally, participants mentioned that implementation of the automation innovation would not have been possible without leveraging existing systems familiar to staff.

##### Barriers to Implementation

Implementation barriers centered on the involvement of staff in the pharmacy service line who had not traditionally been involved in the delivery of nutrition products and services. Key informants described these implementation barriers related to the role of the pharmacy service when implementing the automation of nutrition supports at their site: perceived increase in scope of job role, discomfort with duties outside of expertise, and perceptions of increased work time. Some pharmacy informants described discomfort in working with nutrition supplement products that were beyond their training or perceived scope of practice. Specifically, pharmacists were wary of verifying orders for nutrition products, as they felt they did not have the appropriate expertise. Other key informants stated some pharmacy staff members at their site feared a “slippery slope” of an expansion in the scope for the pharmacy service. As 1 participant noted, “well if we include nutrition supports, what’s stopping them from having us include bandages and gauze?”

Other potential barriers to implementation that were not centered on the pharmacy service included the potential for unclear responsibilities around the product procurement, product quality vetting, and storage of nutrition supports. There was additional resistance to investing the time and energy into new systems and protocols that would be eventually replaced by the upcoming modernization of the VHA electronic health record system. Yet most informants reported that the actual impact of automating nutrition delivery at their sites was minimal, after the initial investment in setting up systems to implement the innovation.

#### Outcomes: What Happens After Implementing the Automation of Nutrition Delivery?

##### Patient Care Quality

Key informants repeatedly emphasized how important the automation of delivering nutrition supports was in assuring high quality patient care for hospitalized Veterans. Automation also allowed more consistency in care between the VHA and partner academic institutions, between inpatient and outpatient care, and in hospital discharge planning. One participant said, “Now I know what the patient got and [at] what frequency, so I can continue that for them at [hospital] discharge.”

##### Patient Safety

Key informants felt automation was important for patient safety in many ways. These included automatic checks for allergies in the system, tracking medication interactions, and reducing administration errors, which all led to decreases in potential harms. Patient safety was also addressed through the enhanced documentation in automated systems, which increased transparency and communication across providers involved in a patient’s care and provided a source of information to document safety incidents to allow for the identification of patterns for future quality improvement efforts. For those informants having experience with BCMA, barcode administration allowed staff to input safety messages on orders or check for interactions with medications, track product expirations, and provide a way to reliably check for non-delivery of nutrition interventions (ie, errors of omission).

##### Staff Workload and Workflow

In general, informants reported that most of their pre-implementation concerns about the negative impacts of automating nutrition support delivery on their workflow and workload did not come to fruition. No informant described that automation made their jobs more difficult or burdensome post-implementation. Specifically, automating the delivery of nutrition support created efficiencies in workload after the initial implementation trial period. Clinical informants stated that standardized quick orders made ordering nutrition supports easier and faster. Food service staff noted the benefits of receiving automatic notices of new orders and patient room changes. Meal costing and reordering of nutrition products on discharge also became easier due to the increased transparency among providers when orders were easily populated and visible in the electronic health record.

Yet automated systems were not seamless. Some informants reported increases in their workload due to the implementation of automated nutrition delivery systems. For staff, much of the increased workload around implementation was reported as being temporary, revolving around the development of the new systems, needs of initial staff training, and early troubleshooting of implementation challenges. Other changes to workflow revolved around increased coordination between departments and negotiation of interdepartmental roles and responsibilities. It was not always clear to those ordering nutrition products how the timing of their orders integrates into other departmental workflows. One informant shared that if an order was a “few minutes too late,” it is possible that a patient could go without nutrition for as long as 12 hours. Additionally, some voiced concerns that the “fit” of automating nutrition delivery into the pharmacy workflow may not be ideal. For example, gaps exist in medicine interaction and food allergen reconciliation.

Several participants noted an ongoing need for pharmacy and nutrition to have cross-training and collaborative opportunities to learn from each other. Last, a change in workload, primarily for leadership, was the increased safety and error reporting resulting from systems capable of error documentation. Yet informants acknowledged these errors were likely existing at higher rates pre-implementation of the automated nutrition systems but with lower ability to detect and document errors. Informants also identified potential changes to workloads due to procurement issues, such as delineating roles and responsibilities for nutrition product storage, or contingency planning for potential shortages. Table 14 details perceived impact of the automation innovation on workload and workflow before and after implementation across VHA job roles.

Table 14 Impact of Automating Delivery of Nutrition Supports on Perceived Workload and Workflow Before and After Implementation

Department/Role | Perceived Impact on Workload and Workflow Before Implementation of AND | Impact on Workload and Workflow After Implementation of AND
Inpatient pharmacists | - Concerns that workload would dramatically increase; - Verifying nutrition orders is outside the scope of pharmacist training | - Nominal impact on workload (~5 orders a week, processed the same as medication); - Established protocols for verifying orders and limiting responsibility within pharmacists’ scope of training; - Errors hardly occurred so management of errors were nominal
Formulary managers BCMA coordinator | - Slippery slope of non-medication additions to BCMA; - Takes more time to source, vet, and secure additional products | - Clear limits placed on the scope of items added to BCMA; - Creation of a new position (Inventory Pharmacy Manager) to take on some duties
Nutritionists/dietitians | - Will increase feedback; - Will reduce order entry time; - Will reduce the need to physically visit patients to determine delivery and proper administration; - Will increase morale: Allows the nutritionists to feel that their work matters/affects patient care | - Increases feedback on interventions; - Reduces order entry time; - Reduces the need to track down what is happening on the floors; - Increases morale: Allows the nutritionists to feel that their work matters/ affects patient care
Nurses | - Concerned about increases in workload, although they wanted to be cued to administer nutrition through the electronic health record and document using BCMA and the electronic health record | - Improved accuracy and timing of delivery with cueing through systems already in use; - Documentation was streamlined into system; - Took no longer than administering a drug; - Entire process improved and simplified workflow
Food service | - Questions about changes in storage and delivery; - Needed to learn and integrate new systems for receiving and creating orders | - No changes in storage and delivery; - Learning new systems took significant effort, trial, and error, but was resolved quickly; - Error reports became more frequent because of increased documentation, creating workload increase for leadership
Information technology | - Increase in items needed to code into the BCMA system; - Needed to develop a system to communicate with food services about nutrition products that need to be delivered to units | - During development phase, spent 4 hours/week on developing the necessary infrastructure; - Slight increase in workload with nutrition products to field barcode changes, additions, and issues

Abbreviations. BCMA=barcode medication administration.

In addition, although we were unable to interview staff in logistics and procurement roles involved in a post-implementation of automation of nutrition delivery, other staff reported the following concerns and impacts:

- Concerns about changes in responsibility for acquisitions, contracts, storage.
- Planning for contingencies like product shortages, recalls, and even small changes in product (eg, change of flavor), which would create larger problems when utilization is determined by barcode.
- Elevating nutrition products to the standards of pharmacy creates increased demand on logistics to vet products to ensure reliability and integrity of vendors and products.

#### Staff Satisfaction and Perceptions of Institutional Reputation

Several informants across different service lines spoke of the positive impact of automating nutrition delivery on their work satisfaction and overall morale as an employee. Nursing service informants reported that they have more system support to effectively implement nutrition interventions, which reduces their work stress. Dietitians reported having more feedback about intervention approaches, increased confidence that their expert recommendations are being implemented, and a more reliable way to evaluate the impact of interventions on patient health. Also, the potential conflict between service lines was alleviated post-implementation through improved verification and follow through on nutrition support orders. As one informant noted, nutritional support BCMA created “more transparency” for all providers involved in patient care and nutrition.

On the contrary, informants also noted the lack of consistency in the automation of nutrition supports across VHA institutions. Informants noted that this type of service is becoming standard at many of the VHA academic partner institutions, while it is still relatively rare in VHA hospitals. VHA staff informants were concerned that Veteran patient customers were comparing the care they receive at each institution; the way that nutrition supports are delivered (or not delivered) factors into these customer service perceptions. As one informant said:

“I was also concerned about the different perceptions of care when nutrition is seamlessly automated in the BCMA system across the street, but not here. I didn't like that they could effectively get an intervention at the university hospital, but not get it when they transferred back to the VA.”