# METHODS

## REGISTRATION AND REVIEW

A preregistered protocol for this review can be found on the PROSPERO international prospective register of systematic reviews (CRD42022347945 (http://www.crd.york.ac.uk/PROSPERO/)). A draft version of this report was reviewed by external peer reviewers; their comments and author responses are located in the Appendix.

## KEY QUESTIONS AND ELIGIBILITY CRITERIA

The following key questions (KQ) were the focus of this review:

- KQ1: What are the effects of automating the delivery of oral, enteral, or parenteral nutrition supports to hospitalized patients on key process, performance, and patient outcomes?
- KQ2: How is automating the delivery of oral, enteral, or parenteral nutrition supports to hospitalized patients experienced by the staff involved in implementing and delivering this innovation?

For this report, nutritional supports can be delivered through any route: oral (by mouth), enteral (through an opening into the digestive system), or parenteral (through a vein). We define automation of nutrition delivery as a process or application of a technology to deliver hospital-based nutrition to patients that minimizes human intervention (ie, “humans” provide the thinking on the ordering side [inputs], and the delivery side [outputs] is automated to minimize touch points). Figure 1 provides a conceptual overview of the potential ways that the nutrition delivery process could be automated, including both automation of a delivery chain step and the potential for automation to trigger documentation that a step has been completed (ie, trigger for human to document step completion). We included studies that assessed automation at any point in the delivery chain, from nutritional assessment and ordering to bedside administration and eventual termination of nutrition supports.

To be included in this review, relevant studies needed to include at least 1 of the following aspects of automation:

- Trigger of documentation of any step starting at nutritional assessment through termination of supplementation;
- Ordering nutrition supports; or
- Delivery of nutrition supports.

Figure 1 Process Map of Hospital-Based Nutrition Delivery

Notes. This process map represents a general process of nutrition delivery in the hospital setting; it may not fully represent the process in every health care setting.

Figure 1 is a diagram depicting the idealized, linear, multi-step process of nutrition delivery in the hospital. The first 2 steps are nutritional screening and documentation of nutritional screening. However, there is a horizontal line indicating that these two steps happen before the steps relevant to this project. The next steps in the pathway include nutritional assessment and nutritional care plan, documentation of the same, ordering/prescription of nutrition, documentation, verifying order, documentation, preparation of nutrition, documentation, administration/delivery of nutrition, documentation, monitoring administration of nutrition, including amount consumed (eg, time, volume, reason for refusal), documentation, end of nutrition treatment, and documentation.

Due to the scope of the KQs in this review, we used different eligibility criteria for each KQ. As KQ1 was focused on effectiveness, we developed eligibility criteria using the PICOTS format (Table 1). The focus of KQ2 was on understanding qualitative experiences with automated nutrition delivery; therefore, we used the SPIDER criteria^30^ to inform eligibility criteria (Table 2).

Table 1 KQ1 PICOTS Eligibility Criteria: Effectiveness of Automated Nutrition Delivery

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Population | Hospitalized patients including long-term care, skilled nursing facility residents, and end-of-life patients who are at risk of malnutrition (ie, who have difficulty eating or absorbing nutrients through gastrointestinal tract). | - Simulated patients; - People with eating disorders
Intervention | Automated nutrition delivery of oral, enteral, or parenteral nutrition supports that includes automated notifications to the hospital care team (eg, nurses and nursing assistants, physicians, pharmacists, food service, registered dietitians) that nutrition supports have been ordered or prescribed and requires responses that the care team has administered nutrition supports and/or how much the patient actually received (eg, electronic health record alerts, barcode scanning). | - Orders only (NPO) (eg, diet orders); - Standard orders without any specialization (ie, admissions orders); - Alert alone, without any other level of alerts or automation (eg, clearing of alerts, further documentation); - Automation of nutraceutical supplementations; - Reminders only; - Patient self-ordering of meals
Comparators | Any comparator (eg, usual care, active comparator, historical controls) | No comparator
Outcome | - Process outcomes (ie, supports delivered, supplement delivery errors); - Performance outcomes (ie, time required for supplement administration, provider satisfaction); - Patient outcomes (ie, calories consumed, macronutrients consumed; body mass index and body weight; length of hospital stay; readmission rate; patient satisfaction); - Patient-level harms (eg, all-cause mortality, pressure injury, falls, organ damage, aspiration, refeeding syndrome) | Any outcomes not listed
Time^a^ | Published after 2000 | Published before 2000
Setting | - Hospital inpatient setting, including inpatient end of life care settings; - Skilled nursing facilities or long-term care settings | - Specialty-specific settings for management of chronic medical conditions (eg, residential obesity care, residential eating disorder care); - Outpatient setting
Study design | - Randomized trials; - Nonrandomized trials; - Controlled before-after studies; - Interrupted time-series studies or repeated measures studies; - Prospective and retrospective observational studies (ie, cohort studies, case control studies); - Cross-sectional; - Pre-post studies | - Descriptive studies with no outcomes data; - Qualitative studies; - Case reports and case studies with no outcome information; - Studies that included only outcomes data from 1 point in time (post only, uncontrolled clinical study); - Modeling studies that used simulated data; - Not a clinical study (eg, editorial, nonsystematic review, letter to the editor)
Countries | OECD^b^ | Non-OECD
Publication types | Full publication in a peer-reviewed journal | Letters, editorials, reviews, dissertations, meeting abstracts, protocols without results

Notes.

a Institute for Safe Medicine Practices (ICMP) established a guideline for standard order sets in 2010 and the Centers for Medicare and Medicaid Services (CMS) published its Conditions of Participation with its first section on standing orders in 2013.

b Organization for Economic Cooperation and Development (OECD) in 2022 includes Australia, Austria, Belgium, Canada, Chile, Colombia, Costa Rica, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Latvia, Lithuania, Luxembourg, Mexico, Netherlands, New Zealand, Norway, Poland, Portugal, Slovak Republic, Slovenia, Spain, Sweden, Switzerland, Turkey, United Kingdom, and United States.

Abbreviations. PICOTS=population, intervention, comparator, outcomes, timing, setting/study design.

Table 2 KQ2 SPIDER Criteria: Experiences with Automated Nutrition Delivery

Study Characteristic | Inclusion Criteria | Exclusion Criteria
Sample | Hospital staff involved in automating the delivery of oral, enteral, or parenteral nutrition supports to patients (eg, nurses and nursing assistants, pharmacists, food service, registered dietitians) | - Other members of staff not involved in the phenomena of interest; - Patients; - Patient informal caregivers
Phenomenon of interest | Experiences of staff using automated nutrition delivery of oral, enteral, or parenteral nutrition supports that include automated notifications to the hospital care team (eg, nurses and nursing assistants, physicians, pharmacists, food service, registered dietitians) that nutrition supports have been ordered/prescribed and requires responses that the care team has administered nutrition supports and/or how much the patient actually received (eg, electronic health record alerts, barcode scanning) | - Orders only (NPO) (eg, diet orders); - Standard orders without any specialization (ie, admissions orders); - Alert alone, without any other level of alerts or automation (eg, clearing of alerts, further documentation); - Automation of nutraceutical supplementations; - Reminders only; - Patient self-ordering of meals
Design | - Studies using qualitative methods for data collection and analysis | Quantitative only designs
Evaluation | Primary purpose was to explore the experiences and attitudes of hospital staff (eg, nursing, pharmacy, food service, dietetics) who interact with some aspect of implementing and delivering the automated delivery of nutrition | Evaluations of patients’ or their informal caregivers’ experiences with the automated delivery of nutrition
Research type | - Qualitative studies (eg, qualitative interviews, focus groups, observations, surveys with open-ended textual data, organizational case studies); - Ethnographies; - Mixed methods studies that report qualitative data | - Quantitative studies with no qualitative component; - Single case study or case reports of a single patient (ie, case study of 1 patient)
Countries | OECD^a^ | Non-OECD
Time^b^ | Published after 2000 | Published before 2000

Notes.

a Organization for Economic Cooperation and Development (OECD) in 2022 includes Australia, Austria, Belgium, Canada, Chile, Colombia, Costa Rica, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Latvia, Lithuania, Luxembourg, Mexico, Netherlands, New Zealand, Norway, Poland, Portugal, Slovak Republic, Slovenia, Spain, Sweden, Switzerland, Turkey, United Kingdom, and United States.

b Institute for Safe Medicine Practices (ICMP) established a guideline for standard order sets in 2010 and the Centers for Medicare and Medicaid Services (CMS) published its Conditions of Participation with its first section on standing orders in 2013.

Abbreviations. NPO=nil per os (ie, nothing by mouth).

## SEARCHING AND SCREENING

To identify articles relevant to the key questions, an expert medical librarian conducted a primary search of MEDLINE (via Ovid), Embase (via Elsevier), and CINAHL from inception to January 16, 2022. We searched databases using a combination of database-specific controlled vocabulary terms and keywords in the titles and abstracts related to nutrition delivery. An experienced medical librarian devised and conducted the search with input on keywords from the other authors. The search strategies were peer reviewed by another librarian using a modified PRESS checklist.^31^ See Appendix for complete search strategies. Titles, abstracts, and full-text articles were reviewed by 1 investigator and checked by another. All disagreements were resolved by consensus or discussion with a third reviewer.

As we did not identify any relevant qualitative studies for KQ2, the methods outlined below focus only on those used for KQ1.

## DATA ABSTRACTION AND RISK OF BIAS ASSESSMENT

We abstracted data from published reports into a customized DistillerSR database. Data were abstracted by 1 reviewer and over-read by a second reviewer. We resolved disagreements by consensus or by obtaining a third reviewer’s opinion. Data elements included descriptors to assess applicability, quality elements, intervention details, and outcomes, including adverse events.

Key characteristics abstracted included participant descriptors (eg, age, sex, race), study design, intervention characteristics (eg, nutrition delivery type, automation type), comparator, and outcomes. We treated multiple reports from a single study as a single data point, prioritizing results based on the most complete and appropriately analyzed data.

We used an adapted Cochrane ROBINS-I tool to assess risk of bias (ROB) for nonrandomized studies^32^ that compare health effects of 2 or more interventions. The ROBINS-I includes domains for (1) confounding; (2) participant selection; (3) intervention classification; (4) deviations from intended interventions; (5) missing data; (6) outcome measurement; and (7) selective outcome reporting. Overall, ROB judgments included low ROB, serious ROB, critical ROB, and no information. For randomized trials, we adapted the Cochrane (RoB2) tool.^33^ This tool includes the following domains: (1) bias arising from the randomization process; (2) bias due to deviations from intended interventions; (3) bias due to missing outcome data; (4) bias in measurement of the outcome; (5) bias in selection of the reported result and has overall ROB as low, some concerns, or high ROB. Lastly, we used NIH Cross-sectional Tool Risk of Bias for cross-sectional designs,^34^ which includes 14 items that assess the risk of potential selection bias, information bias, measurement bias, or confounding. Studies were assigned an overall rating of good, fair, or poor ROB. All ROB assessment was completed independently by 2 investigators. Disagreements were resolved by consensus or by consulting a third investigator. (See Appendix for risk of bias ratings.)

## SYNTHESIS

We summarized the primary literature using relevant data abstracted from the eligible studies and developed summary tables to describe key study characteristics of included studies (eg, study design, intervention details). We then determined the feasibility of completing a quantitative synthesis (ie, meta-analysis) to estimate summary effects. Feasibility of meta-analysis depended on the conceptual homogeneity of the studies based on study design (eg, randomized trials versus non-randomized EPOC studies), intervention (ie, type of automation), outcome features (eg, outcomes measuring the same underlying concept at a similar timepoint), and completeness of results reporting. Further, we aggregated outcomes when there were at least 3 studies with the same outcome, based on the rationale that 2 studies do not provide adequate evidence for summary effects.

When quantitative synthesis was possible, we used random-effects meta-analysis models to pool available outcome data. Continuous outcomes were synthesized as mean differences when all studies used the same outcome measure and as standardized mean differences (Hedges’ g) when different measures of the same construct were reported. Dichotomous outcomes were pooled using odds ratios. When studies with dichotomous outcomes reported zero outcome events, we utilized hypergeometric-normal models to avoid the need for continuity corrections (a continuity correction of 0.5 was added to all counts of studies with zero cells only when generating study-level odds ratios in forest plots). For analyses with fewer than 20 studies, we used the Knapp-Hartung approach to adjust standard errors of the estimated coefficients. We evaluated statistical heterogeneity using visual inspection of forest plots and 95% prediction intervals. Meta-analyses were conducted using the metafor package for R (R Foundation for Statistical Computing, Vienna, Austria).^35^

When a quantitative synthesis was not feasible, we narratively analyzed data. We emphasized evidence from higher quality studies with more precise estimates of effect. The narrative synthesis focused on documenting and identifying patterns in efficacy and safety of interventions across conditions and outcome categories. We interrogated potential reasons for inconsistency in treatment effects across studies by comparing differences in study population, intervention, comparator, and outcome definitions.

### Strength of Evidence

We assessed the certainty of evidence (COE) for KQ1 using the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group process.^36^ We limited GRADE ratings to those outcomes identified by the VHA stakeholders and technical expert panel as critical to decision-making (ie, provider satisfaction, nutrition supports delivered, errors). In brief, the GRADE approach requires assessment of 4 domains:

- Risk of bias (eg, Are there major limitations in included study designs for this outcome?)
- Consistency of effects (eg, Do point estimates vary widely across studies on this outcome?)
- Directness (eg, Are we confident the evidence directly compares interventions of most interest to key stakeholders? Are these interventions assessed in populations of interest to key stakeholders?)
- Precision (eg, For this outcome, are there relatively few patients? Are the 95% confidence intervals wide?)

Additional domains used were coherence, dose-response association, impact of plausible residual confounders, strength of association (magnitude of effect), and publication bias, as appropriate. These domains were considered qualitatively; we assigned a summary COE rating after discussion by 2 investigators (AMG, JMG). In keeping with GRADE guidelines, we also provided separate COE ratings for randomized studies and observational studies.

## PRIMARY QUALITATIVE INQUIRY METHODS

A key need for VA operational partners was better understanding the experiences and perceptions of staff who had implemented some type of automation of nutrition delivery. As we anticipated that there may be a low yield for KQ2 (qualitative evidence synthesis), we designed and conducted a primary qualitative study to explore staff perspectives on, and experiences with, automated nutrition delivery innovations within the VHA.

The Durham VA institutional review board (IRB) reviewed and designated this study as quality improvement. A trained qualitative interviewer (AS) conducted semi-structured individual interviews with staff involved in the implementation. As mandated by the VHA, no potential key informants were approached about this study until we had obtained approvals from national VHA union representatives.

### Research Question

The following research question was the focus of this primary qualitative inquiry: How is automating the delivery of oral, enteral, or parenteral nutrition supports to hospitalized patients experienced by the staff involved in implementing and delivering it?

### Key Informant Participants

Eligible qualitative interview key informant participants included VHA-employed staff and leadership who had interacted with some form of automation of nutrition supports at a VHA hospital. We intentionally sought to include a diverse set of key informants as defined by their roles within the VHA (eg, food service delivery, nursing, pharmacy service). We recruited key informants via email after being identified by VHA operational partners as those who have direct experience with the innovation. We also used snowball recruitment: at the conclusion of each qualitative interview, we asked the key informant to help identify other potential VHA staff with relevant expertise in automating the delivery of nutritional supports in the VHA. Key informants were not compensated for their time.

### Positionality

Our qualitative team represents diverse backgrounds in terms of age, educational attainment, and lived experience with VHA quality improvement projects. We acknowledge that our positionality can influence this project. As such we adhered to qualitative methodological standards that promote trustworthiness and credibility. These methods included practicing reflexivity, maintaining an audit trail of analytic decisions, employing standardizing procedures such as an intercoder reliability process, and incorporating member checking.

### Qualitative Data Collection

We designed a semi-structured qualitative interview guide (Appendix) to elicit information about how automating the delivery of oral, enteral, or parenteral nutrition supports to hospitalized patients was experienced by the staff involved in implementing and delivering this innovation. For example, we asked about the key informant’s role in automating nutrition delivery, how the innovation fit into their workflow, how it impacted resources, and what barriers and facilitators they experienced when implementing the intervention. Interviews were conducted by a trained qualitative interviewer (AS) using MS Teams videoconferencing software; they were audio recorded and auto-transcribed, and they lasted an average of 27.8 minutes (range: 12.9–47.13).

### Qualitative Analysis

We analyzed interview data using rapid qualitative analysis methods common in health services quality improvement research.^37^ Interview transcripts and structured interviewer notes were reviewed by the qualitative team (AS, JDS) and edited for clarity. We then summarized the notes into a matrix guided by the structure of the interview guide. Further analyses consisted of iterative dyad-level memo development and matrix analyses^38^ to elucidate common and contrasting experiences and identify themes. Each team member reviewed a subset of the other’s work and resolved coding disagreements through regular coder discussion and consensus.