# BACKGROUND

Optimal nutrient intake is crucial for patients’ health during a hospital stay.^1,2^ Yet hospital malnutrition is a common condition that often goes undiagnosed and untreated.^3^ It is estimated that 40% of patients are malnourished during their hospitalization, which may lead to muscle loss, delayed wound healing, increased risk of infection, prolonged hospitalization, and mortality.^1,4^

The provision of optimal nutrition support during hospitalization is challenging due to variability in timing, delivery route, dose, and type of nutrients provided. Also, many patients at nutritional risk suffer from multiple comorbidities that need to be accounted for when implementing a nutrition support plan that maximizes patient safety. Patient experiences with hospital nutrition also influence overall perception of care and satisfaction during hospitalization.^1,4^ Yet the provision of inpatient nutrition supports is not without risk. Several studies have documented common errors and safety events related to the provision of inpatient nutrition supports.^5,6^ To address the delivery of optimal nutrition support, many health care organizations have adopted automation technology as a promising practice to improve patient safety and satisfaction with care, nutrition support accuracy, and delivery efficiency.^3,7,8^

Inpatient nutrition support includes screening and assessment, ordering appropriate nutrition supports, preparation of products, delivery and administration, monitoring, and termination of nutrition supports. The automation of nutrition delivery can target 1 or several of these steps, and conceivably, automated tools could be integrated into a comprehensive computerized system encompassing ordering through administration at the patient’s bedside. Key examples of nutrition delivery innovations include computerized provider order entry (CPOE), clinical decision support (CDS), or barcode medication administration (BCMA) and electronic Medication Administration Record (eMAR).^9,10^ CPOE refers to a variety of computer systems for ordering medications that ensure standardized, legible, and complete orders. A CDS system can vary in complexity but often includes suggestions or default values for nutrient doses, routes, and frequencies. Some CDS provides reminders for corollary orders (eg, glucose checks before nutrition intake) and clinical guidelines (eg, decision trees for amount of nutrient at time of ordering). More complex CDS can check for allergies, laboratory values, interactions, and contraindications.

The third example, BCMA and eMAR, employs patient-specific wristbands and barcodes to electronically ensure the “five rights of medication administration”: the right medication, right dose, and right route at the right time for the right patient.^9,11^ These eMAR barcode systems have the ability to automatically document the administration of medication into a patient’s electronic health record. The US Food and Drug Administration (FDA) has mandated barcodes for thousands of medications and products.^12^ While these barcodes are mandated only for products produced by drug suppliers, the FDA ruling has encouraged technological advancements like BCMA for other products like delivery of nutrition supports.^13^

While the main goals of automating nutrition delivery are to improve patient safety and maximize delivery efficiency and nutrition support accuracy, the shift to automated nutrition innovations may have unintended impacts on hospital staff. Specifically, introducing automation may alter or even hinder the routines of the health care staff. Consequently, staff may adapt their decision-making processes and activities to comply with new technology systems.^9,14^ Although evidence indicates that automation technology can improve patient safety,^15–18^ automation also has the potential to cause patient harm.^19–21^ Favorable outcomes in nutrition support depend on several factors, including an implementation process that facilities the integration of the innovation into existing workflows.^22,23^ When hospital staff experience workflow conflicts between their standard duties and new innovation implementation tasks, staff may develop implicit or explicit procedures to reject the innovation (eg, develop workarounds).^9,10,24^

Using automation processes to deliver nutritional supports to hospitalized patients has the potential to address many aspects of the Quintuple Aim for health care improvement.^25^ Recently, several national profession societies and institutions, such as the Institute for Safe Medication Practices,^26^ have advocated for innovations to support the provision of nutritional products to hospitalized patients to reduce errors and maximize the safety and quality of care.^27–29^ Yet it is unknown which forms of automation are optimal and to what degree automation optimizes key clinical and patient outcomes. Also, it is unknown how hospital staff implementing and delivering nutrition supports added by automation experience such innovations. To address these questions, we conducted a systematic review of quantitative and qualitative peer-reviewed literature evaluating the impact of automated nutrition delivery systems in the context of inpatient care. The VHA Nutritional Field Advisory Board requested this review to inform clinical guidance and implementation methods to optimize nutrition delivery to hospitalized Veterans.