# ABBREVIATIONS TABLE

Abbreviation: Definition
AND: Automated nutrition delivery
BCMA: Barcode medication administration
CDS: Clinical decision support
CMS: Centers for Medicare and Medicaid Services
CPOE: Computerized provider order entry
ISMP: Institute for Safe Medication Practices
MAR: Medication administration record
NICU: Neonatal intensive care unit
PICU: Pediatric intensive care unit
PN: Parenteral nutrition
TPN: Total parenteral nutrition