# REFERENCES

1 Vespa JE, Armstrong DM, Medina L. Demographic turning points for the United States: Population projections for 2020 to 2060. US Department of Commerce, Economics and Statistics Administration, US …; 2018.
2 Vespa J. Aging veterans: American’s veteran population in later life. US Census Bureau; 2023.
3 Aging NCo. Chronic Inequities: Measuring Disease Cost Burden Among Older Adults in the US A Health and Retirement Study Analysis. 2022.
4 Guth A, Chou J, Courtin SO, Ford C, Hennawi G, Brandt N. An Interdisciplinary Approach to Implementing the Age-Friendly Health System 4Ms in an Ambulatory Clinical Pathway With a Focus on Medication Safety. Journal of Gerontological Nursing. 2020;46(10):7–11. doi:10.3928/00989134-20200909-02
5 Emery‐Tiburcio EE, Berg-Weger M, Husser EK, The geriatrics education and care revolution: diverse implementation of age-friendly health systems. Journal of the American Geriatrics Society. 2021;69(12):E31–E33.34624931
6 Powers JS, Penaranda N. Creation of a Whole Health Age-Friendly Template and Dashboard Facilitates Implementation of 4Ms into Primary Care. Geriatrics (Basel, Switzerland). 2022;7(5)doi:10.3390/geriatrics7050109
7 Collins LM, Murphy SA, Strecher V. The multiphase optimization strategy (MOST) and the sequential multiple assignment randomized trial (SMART): new methods for more potent eHealth interventions. Am J Prev Med. May 2007;32(5 Suppl):S112–8. doi:10.1016/j.amepre.2007.01.022 17466815
8 Landes SJ, McBain SA, Curran GM. An introduction to effectiveness-implementation hybrid designs. Psychiatry Res. Oct 2019;280:112513. doi:10.1016/j.psychres.2019.112513 31434011
9 Smith JD, Li DH, Rafferty MR. The Implementation Research Logic Model: a method for planning, executing, reporting, and synthesizing implementation projects. Implement Sci. Sep 25 2020;15(1):84. doi:10.1186/s13012-020-01041-8 32988389
10 Damschroder LJ, Reardon CM, Widerquist MAO, Lowery J. The updated Consolidated Framework for Implementation Research based on user feedback. Implement Sci. Oct 29 2022;17(1):75. doi:10.1186/s13012-022-01245-0 36309746
11 Glasgow RE, Harden SM, Gaglio B, RE-AIM Planning and Evaluation Framework: Adapting to New Science and Practice With a 20-Year Review. Front Public Health. 2019;7:64. doi:10.3389/fpubh.2019.00064 30984733
12 RE-AIM: Improving Public Health Relevance and Population Health imapct. https://re-aim.org/.
13 Types of Health Care Quality Measures. . Agency for Healthcare Research and Quality. Updated Content last reviewed July 2015. . https://www.ahrq.gov/talkingquality/measures/types.html
14 Waltz TJ, Powell BJ, Matthieu MM, Use of concept mapping to characterize relationships among implementation strategies and assess their feasibility and importance: results from the Expert Recommendations for Implementing Change (ERIC) study. Implement Sci. Aug 7 2015;10:109. doi:10.1186/s13012-015-0295-0 26249843
15 Powell BJ, Waltz TJ, Chinman MJ, A refined compilation of implementation strategies: results from the Expert Recommendations for Implementing Change (ERIC) project. Implement Sci. Feb 12 2015;10:21. doi:10.1186/s13012-015-0209-1 25889199
16 Guyatt GH, Oxman AD, Vist GE, GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. Bmj. Apr 26 2008;336(7650):924–6. doi:10.1136/bmj.39489.470347.AD 18436948
17 Berish D, Husser E, Knecht-Fredo J, Collaborating toward equity in Pennsylvania: The Age-Friendly Care, PA project. Health Services Research. 2023;58(S1):78–88. doi:10.1111/1475-6773.14073
18 Garbarino JT, O'Connor S, Pepin RL, Aitken MS, Flaherty E. Age-friendly health care and the 4Ms in RN-led annual wellness visits. Journal of the American Geriatrics Society. 2023;doi:10.1111/jgs.18671
19 Lundy J, Hayden D, Pyland S, Berg-Weger M, Malmstrom TK, Morley JE. An Age‐Friendly Health System. Journal of the American Geriatrics Society. 2021;69(3):806–812. doi:10.1111/jgs.16959 33275785
20 Pohnert AM, Schiltz NK, Pino L, Achievement of age-friendly health systems committed to care excellence designation in a convenient care health care system. Health Services Research. 2023;58(S1):89–99. doi:10.1111/1475-6773.14071 36134714
21 Tewary S, Cook N, Pandya N, Damier S, Shnayder O, Dezine M. Using the 4M framework of the Age-Friendly Health System to improve MIPS documentation in primary care clinics: A quality improvement study. Gerontology & Geriatrics Education. 2023;44(4):631–640. doi:10.1080/02701960.2022.2117171 36062563
22 Tewary S, Cook N, Simon D, Philippe E, Shnayder O, Pandya N. Integrating 4Ms Assessment through Medicare Annual Wellness Visits: Comparison of Quality Improvement Strategies in Primary Care Clinics. Geriatrics (Basel, Switzerland). 2023;8(4)doi:10.3390/geriatrics8040070
23 Vonnes C, El-Rady R. Implementing the 4 Ms in a Geriatric Oncology Clinic to Create Age Friendly Cancer Care. Geriatr Nurs. 2023;71(54):365–368. doi:10.1111/jgs.18336
24 Wismann A, Kleszynski K, Jelinek D, An age-friendly approach to primary care in an academic health system. Journal of the American Geriatrics Society. 2024;doi:10.1111/jgs.18848
25 Proctor EK, Powell BJ, McMillen JC. Implementation strategies: recommendations for specifying and reporting. Implement Sci. Dec 1 2013;8:139. doi:10.1186/1748-5908-8-139 24289295
26 Church K, Munro S, Shaughnessy M, Clancy C. Age-Friendly Health Systems: Improving care for older adults in the Veterans Health Administration. Health Serv Res. Feb 2023;58 Suppl 1(Suppl 1):5–8. doi:10.1111/1475-6773.14110
27 Kalsy M, Church K, Bowman E, Mirk A, Olunuga D, Edes T. Shifting Culture Toward Age-Friendly Care: Lessons From VHA Early Adopters. Fed Pract. Oct 2023;40(10):344–348b. doi:10.12788/fp.0420 38567299
28 Adler-Milstein JR, Krueger GN, Rosenthal SW, Rogers SE, Lyles CR. Health system approaches and experiences implementing the 4Ms: Insights from 3 early adopter health systems. Journal of the American Geriatrics Society. 2023;71(8):2627–2639. doi:10.1111/jgs.18417 37246845