# ACKNOWLEDGMENTS

The authors are grateful to Cheryl Banick, MLIS, and Gaelen Adam, MLIS, PhD, and Becky Baltich Nelson, MLS, MS, for literature searching and retrieval, Anayah Sanders for study screening, Jennifer L Sullivan, PhD and Jane A Driver, MD, MPH for their consultation, and the following individuals for their contributions to this project:

## Operational Partners

Operational partners are system-level stakeholders who help ensure relevance of the review topic to the VA, contribute to the development of and approve final project scope and timeframe for completion, provide feedback on the draft report, and provide consultation on strategies for dissemination of the report to the field and relevant groups.

- Kimberly Church Wozneak, MS
  National Lead for Age-Friendly Health Systems
  Office of Geriatrics and Extended Care
- Marianne Shaughnessy, PhD
  Director - Geriatrics Research and Clinical Center Programs
  Office of Geriatrics and Extended Care

## Technical Expert Panel

To ensure robust, scientifically relevant work, the technical expert panel (TEP) guides topic refinement; provides input on key questions and eligibility criteria, advising on substantive issues or possibly overlooked areas of research; assures VA relevance; and provides feedback on work in progress. TEP members included:

- Andrea Schwartz, MD, MPH, AGSF
  Associate Director for Clinical Innovation
  New England Geriatrics Research Education and Clinical Center (GRECC), VA Boston Healthcare System
- Robert Burke, MD, MS
  Principal Investigator
  VA Center for Health Equity Research and Promotion (CHERP), Philadelphia VA Medical Center
- Julia Adler-Milstein, PhD
  Professor of Medicine
  University of California, San Francisco
- Mary Dolansky, PhD, RN, FAAN
  Associate Professor, Department of Population and Quantitative Health Sciences, School of Medicine Director, Sarah Cole Hirsh Institute, Frances Payne Bolton School of Nursing Associate Director for Clinical Innovation
  Frances Payne Bolton School of Nursing Associate Director for Clinical Innovation