# Executive Summary

## KEY FINDINGS

Contextual factors (barriers and facilitators) affecting implementation of age-friendly health system (AFHS) programming:

► Barriers to AFHS implementation included challenges with data collection and documentation; difficulty changing culture, engaging team members, or establishing new processes; lack of buy-in or What Matters, Medication, Mentation, and Mobility (4Ms) knowledge; patient preferences; scheduling/time constraints; and technology barriers.
► Facilitators to AFHS implementation included buy-in; administrative support or existing infrastructure; 4Ms knowledge; and partnerships/community support.

Effect of strategies to increase the uptake of 4Ms in sites with existing AFHS programming:

► A general combination of strategies to increase the uptake of AFHS may improve What Matters (low confidence), Mobility (low confidence), and composite 4Ms process measures (moderate confidence).
► There is insufficient evidence to assess the effects of a general combination of AFHS strategies for Medication and Mentation process measures (no conclusion).
► There is insufficient evidence for the effect of a specific strategy or specific combination of strategies on What Matters, Medication, Mentation, and Mobility or composite 4Ms (no conclusion).
► No study reported results for outcome or structural measures or results based on patient- or system-level factors.

Effect of AFHS implementation in sites without existing AFHS programming:

► There is insufficient evidence to assess the effect of a specific strategy, specific combination of strategies or overall implementation of AFHS on What Matters, Medication, Mentation, and Mobility or composite measures of 4Ms (no conclusion).
► A general combination of implementation strategies may improve What Matters, Medication, Mentation, and Mobility process measures over time after AFHS implementation (moderate confidence).
► No study examined outcome or structural measures or results based on patient-level factors. Only 1 study reported results by system-level factors (internal medicine, family medicine, geriatrics), and found a geriatric clinic had the largest improvement in 4Ms process measures after implementation of general strategies.

Future research:

► There is a need to standardize the reporting of AFHS implementation strategies, and 4Ms process and outcome measures.
► There is a need for research to examine the effect of specific AFHS implementation strategies on process and outcome measures.

The US Veteran population is rapidly aging and almost half of all Veterans are aged 65 or older. Delivery of health care services to older adults can be challenging, fragmented, and poorly coordinated, which can lead to duplication of services and care that may not address patient-centered needs. In 2017, the John A. Hartford Foundation, the Institute for Healthcare Improvement (IHI), the American Hospital Association (AHA), and the Catholic Health Association (CHA) of the US jointly launched the Age-Friendly Health System (AFHS) initiative. The goal of the AFHS is to improve care and outcomes for older adults, and the foundation of AFHS is the “4Ms” framework:

- What Matters: Aligning care with patient goals and preferences.
- Medications: Emphasizing age-appropriate medications.
- Mentation: Addressing depression, dementia, and delirium across care settings.
- Mobility: Promoting safe movement to maintain function.

In March 2020, the Veterans Health Administration (VHA) joined the AFHS initiative with the goal to have every Veteran aged 65 and older receive AFHS care at every encounter. To support the implementation of AFHS in VHA, the Office of Geriatrics and Extended Care (GEC) has led implementation and dissemination support by creating a community of practice. GEC is hosting a State-of-the-Art Conference in mid-2025 to identify the barriers and facilitators to AFHS dissemination and sustainment and define a research agenda focused on AFHS care within VHA.

## CURRENT REVIEW

The VHA Office of GEC requested the following systematic review to examine the barriers and facilitators to AFHS implementation and the evidence on strategies to implement AFHS in outpatient settings. The following key questions (KQs) were developed in collaboration with VA partners:

1. What are the contextual factors for implementation of AFHS in outpatient settings?
2a. What is the effect of implementation support strategies on process, outcome, and structural measures of AFHS in outpatient settings?^i^
2b. Do process, outcome, and structural measures differ based on patient or system factors (such as race, ethnicity, or rurality)?^i^

We searched for peer-reviewed articles in Ovid (Medline), EMBASE, CINAHL, Cochrane, and clinicaltrials.gov (http://clinicaltrials.gov) from 2015 to March 28, 2024. Eligible records included qualitative or mixed methods studies (KQ1 only), randomized controlled trials (RCTs), non-randomized controlled studies (NRCS), and single group studies. For both KQ1 and KQ2, eligible studies included people aged 65 and older, as well as outpatient systems (including convenient care clinics, non-urgent care walk-in clinics, or dental settings), providers, or staff that serve these individuals. Studies reported on the implementation of AFHS (had to assess or act on all 4Ms). We excluded studies using definitions of age-friendly that differed from the IHI AFHS, studies focusing on supporting other models of care, studies not implementing all 4Ms, interventions for students/trainees who were not offering unsupervised patient care, and educational interventions only assessing changes in knowledge or attitudes. For KQ1, barriers and facilitators for implementation of AFHS (qualitative data) were classified using the updated Consolidated Framework for Implementation Research (CFIR 2.0). For KQ2, we analyzed the effect of implementation strategies on process (eg, proportion of patients screened for depression, fidelity to intervention protocols), outcome (eg, number of patient falls), and structural measures (eg, number of sites recognized as age-friendly) based on the Agency for Healthcare Research and Quality’s Health Care Quality Measure categorization. We also used Waltz’s 9 clusters of strategies (derived from the original strategies of the Expert Recommendations for Implementing Change project) to categorize the implementation strategies employed in each study. We assessed certainty of evidence following the GRADE (Grading of Recommendations Assessment, Development and Evaluation) approach. Studies with only post-data were excluded from our GRADE assessments. Certainty of evidence was not assessed for KQ1.

## RESULTS

Ten studies conducted in the US between 2015 and 2023 were eligible and included for both KQ1 and KQ2. Only 1 mixed methods study formally assessed barriers and facilitators affecting AFHS implementation; however, the 9 other studies reported barriers and facilitators mostly in the discussion section. Four studies (1 NRCS, 2 pre-post studies, and 1 post-only study) reported results for sites that sought to increase the uptake of existing AFHS programming. One of the pre-post studies reported results before and after implementation of strategies to increase the uptake of AFHS in 2 VA Medical Centers. Seven studies (5 pre-post studies or baseline-later time point, and 2 post-only studies) reported results for implementation of AFHS strategies at sites that did not already offer AFHS programming. One study reported results for sites with a mix of existing and new AFHS programming. In 9 studies, the number of patients varied from 116 to 6,924 and 1 multi-facility study included more than 300,000 patients. There were limited data on patient demographics. Only 1 study reported patient gender (61% female) and 2 reported patient race or ethnicity (White 47.2% to 96%, Black 4.2% to 40%, Hispanic 2.7% to 9.2%, and Asian 1% to 3.4%).

### Description of Implementation Support Strategies

The 10 studies employed 67 implementation strategies (mean = 5.6 strategies per study, range = 2–20), aligning with all 9 of the Waltz clusters (mean = 4.5 clusters per study, range = 3–7). Eleven studies implemented the strategy cluster support clinicians. An example of this strategy included creating reminders about the 4Ms in the electronic medical record. Nine studies used the strategy cluster change infrastructure. One example of a strategy in this cluster was the implementation of a templated note in the electronic medical record. Eight studies used the strategy cluster train and educate shareholders. One example of this approach included providing peer consultations. Seven studies used the strategy cluster evaluative and iterative strategies. An example of this approach included utilizing data dashboards and other forms of performance feedback. Six studies used the strategy cluster engage consumers. One example of a strategy in this cluster was using pocket cards about the 4Ms to engage patients as active participants in their care. Six studies used the strategy cluster develop shareholder interrelationships. An example of a strategy in this cluster is using interprofessional teams. Four studies used the strategy cluster adapt and tailor to context. One example of a strategy in this cluster was the use of data experts or tailoring strategies. Two studies used the strategy cluster provide interactive assistance, which included, as an example, using an experienced practice facilitator. Finally, 1 study used financial incentives for the completion of the 4Ms.

### Contextual Factors (Barriers and Facilitators) Affecting Implementation of AFHS Programming

Only 1 mixed methods study formally assessed barriers and facilitators affecting AFHS implementation. This study was conducted in 5 primary care clinics (1 geriatrics clinic, 1 internal medicine clinic, and 3 family medicine clinics). The remaining 9 studies did not formally assess barriers and/or facilitators. However, these studies did qualitatively note barriers and/or facilitators largely in the discussion section of the articles and they were like those described in the mixed methods study.

#### Barriers

Six studies reported 20 unique barriers coded to the Inner Setting domain of CFIR 2.0. Barriers in the Inner Setting included challenges with data collection and documentation; difficulty changing culture, engaging other team members, or establishing new processes; lack of buy-in or 4Ms knowledge; patient preferences; scheduling/time constraints; technology barriers; and factors not categorized elsewhere. For the Individual domain (10 unique barriers, 6 studies), barriers included challenges with data collection and documentation; difficulty changing culture, engaging other team members, or establishing new processes; lack of buy-in or 4Ms knowledge; patient preferences; scheduling/time constraints; and factors not categorized elsewhere. For the Implementation Process domain (10 unique barriers, 7 studies), factors included challenges with data collection and documentation; difficulty changing culture, engaging other team members, or establishing new processes; lack of buy in or 4Ms knowledge; patient preferences; and technology barriers. The Outer Setting domain included 1 barrier in 1 study (reduced training participation due to COVID).

#### Facilitators

For the Inner Setting domain (8 unique facilitators, 4 studies), facilitators included buy-in; administrative support or existing infrastructure; clinical team knowledge of the 4Ms; and factors not classified elsewhere. For the Individual domain (8 unique facilitators, 5 studies), facilitators included buy-in; administrative support or existing infrastructure; and clinical team knowledge of 4Ms. For the Implementation Process domain (6 unique facilitators, 3 studies), facilitators included administrative support or existing infrastructure; stakeholder partnerships/ community support; and factors not classified elsewhere. For the Outer Setting domain (3 unique facilitators, 3 studies), facilitators included stakeholder partnerships/community support and patient resources.

### Effect of Strategies to Increase the Uptake of 4Ms in Sites With Existing AFHS Programming

Four studies reported results from sites that implemented strategies to increase the uptake of AFHS in outpatient setting with existing AFHS programming. One NRCS compared 2 different strategies to sites that did not implement these strategies, 2 studies reported measures before and after (ie, pre-post) implementation of strategies, and 1 study only reported results after AFHS strategy implementation without any baseline data. Three studies were conducted in outpatient clinics (sample size = 146 to 176, with 1 study not reporting number of patients included) and 1 study was conducted in multiple convenient care clinics (sample size not provided for this analysis). The study with post-only data and 1 pre-post study had unclear reporting of outcomes and unclear eligibility criteria (therefore, high risk of bias). The other pre-post study was rated as moderate risk of bias due to only reporting on a small number of patients during the post-intervention period. The 1 NRCS was moderate risk of bias due to unclearly defined outcomes.

The studies found that a general combination of strategies to increase the uptake of AFHS may improve What Matters (2 studies; low confidence), Mobility (2 studies; low confidence), and composite 4Ms process measures (2 studies; moderate confidence). Evidence is insufficient to assess the effects of a general combination of strategies on the uptake of Medication and Mentation process measures (no conclusion). Evidence is insufficient for the effect of a specific strategy or specific combination of strategies on the uptake of What Matters, Medication, Mentation, and Mobility or composite 4Ms (no conclusion). No study reported results for outcome or structural measures or results based on patient or system level factors, such as race or ethnicity of patients, or rurality of systems.

### Effect of AFHS Implementation in Sites Without Existing AFHS Programming

Seven studies reported results for outpatient clinics that implemented AFHS at sites that did not already offer AFHS programming. Three studies reported pre-post results, 2 studies compared a baseline implementation period to a later time point of implementation (ie, baseline-later time point), and 2 studies reported results at a single time post-intervention (ie, post-only). There were 3 multi-center studies and 4 single center studies. One very large study included 324,245 patients and the remaining 6 included 19,795 patients. Three pre-post studies had high risk of bias due to uncertainty about completeness of follow up data, unclear reporting, lack of fully defined outcomes, unclear representativeness of the cohort, and other biases not classified elsewhere. One study that compared a baseline implementation to a later time of implementation was moderate risk of bias due to lack of fully defined outcomes. One study that compared baseline implementation to a later timeline of implementation was rated as low risk of bias. The 2 studies that reported post-only data had unclear representativeness of the cohort, unclear eligibility criteria, and lack of fully defined outcomes (therefore, high risk of bias).

The studies provide insufficient evidence for the effect of a specific strategy, combination of strategies, or overall implementation of AFHS on What Matters, Medication, Mentation, and Mobility or composite measures of 4Ms (no conclusion). Implementation of general strategies may improve What Matters (2 studies), Medication (2 studies), Mentation (2 studies), and Mobility (2 studies) process measures after an initial implementation phase (moderate confidence for all). No studies examined outcome or structural measures or results based on patient-level factors. One study reported results by system-level factors (internal medicine, family medicine, geriatrics), and found a geriatric clinic had the largest improvements in 4Ms process measures after implementation of general strategies.

## DISCUSSION

VHA is emerging as a leader of AFHS in the US, demonstrating remarkable growth since joining the initiative in March 2020. The initial goal of building the AFHS community within VA has been successfully achieved, setting the stage for broader implementation. As VHA aims to scale implementation of AFHS, VHA leadership needs practical and replicable guidance on the strategies they should use to implement AFHS. Although we identified 10 studies that reported data on organizations that implemented AFHS in an outpatient setting, none of the studies explicitly specified strategies (eg, actor, action, temporality, or dose). The lack of detail makes it challenging to replicate or generalize strategies to health systems that aim to implement AFHS. Overall, the implementation of AFHS strategies may improve the uptake of 4Ms in sites that already have AFHS programming. Additionally, the use of general strategies to implement AFHS in sites without existing AFHS programming may improve 4Ms process measures. Importantly, all but 1 study explicitly attempted to evaluate the effect of a specific strategy on implementation. Unfortunately, the evidence base is insufficient to provide recommendations for the specific implementation strategies that should be used.

Ultimately, successful implementation will likely require multiple strategies tailored to the local context.

Future studies should address several gaps in the current evidence base. These include the need to standardize the measures of AFHS implementation (ie, strategies), which would allow for comparable analyses across settings and populations and could help sites when planning to implement AFHS. There is a large need for research to examine the effect of specific strategies on process and outcome measures to determine and disseminate the most effective implementation strategies. VHA can take the lead in building a detailed registry of implementation strategies, which would provide a valuable foundation to ultimately evaluate the effectiveness of specific strategies. There is also a need to improve the measurement of process and outcome measures related to AFHS implementation, and a need for global measures of AFHS implementation—measures that go beyond individual Ms such as quality of life, home days, and patient and caregiver experience. VHA can lead in developing a common measurement set to evaluate process and outcome measures across VHA sites.

There are several strengths and limitations to this systematic review. We employed standard systematic review methodology and existing frameworks including the Waltz strategy clusters to frame the analyses. However, the complexity of the interventions prevented us from quantitatively synthesizing findings or being able to determine the effect of specific strategies on prioritized process and outcome measures. Importantly, we limited our evaluation to studies that described the use of strategies to implement the AFHS and reported structural, process, or outcome measures. This resulted in excluding some studies that described strategies to implement AFHS but only reported educational outcomes. Furthermore, we did not extract data on the pre-implementation processes that were often described by studies and that informed the specific implementation strategies.

## CONCLUSIONS

AFHS transformation requires strategic guidance based on both scientific literature and pragmatic experience from current AFHS implementation. Existing evidence on AFHS implementation strategies in outpatient settings is mostly insufficient to assess the effects of these strategies on implementation outcomes. Nonetheless, using some combination of strategies appears to improve 4Ms process measures. Limitations to available studies underscore the need for more research on AFHS implementation, increased standardization of implementation measures, and greater use of outcome measures that are important to health care leadership, clinicians, and patients.

i Originally framed as reach, effectiveness, adoption, implementation, and maintenance based on the RE-AIM framework.