# DISCUSSION

We identified 4 studies that reported on the implementation of strategies to increase the uptake of AFHS at sties with existing AFHS programming, and 7 studies that reported on the implementation of AFHS at sites without existing AFHS programming. One pre-post study was conducted in 2 VA Medical Centers. The 10 studies predominantly reported process measures. One mixed-methods study explicitly examined barriers and facilitators to implementation. Key findings include the following:

## KEY FINDINGS

For contextual factors (barriers and facilitators) affecting implementation of AFHS, key findings are:

- Barriers to AFHS implementation included challenges with data collection and documentation; difficulty changing culture, engaging team members, or establishing new processes; lack of buy-in or 4Ms knowledge; patient preferences; scheduling/time constraints; and technology barriers.
- Facilitators to AFHS implementation included buy-in; administrative support or existing infrastructure; 4Ms knowledge; and partnerships/community support.

For the effect of strategies to increase the uptake of 4Ms in sites with existing AFHS programming, key findings are:

- A general combination of strategies to increase the uptake of AFHS may improve What Matters (low confidence), Mobility (low confidence), and composite 4Ms process measures (moderate confidence).
- There is insufficient evidence to assess the effects of a general combination of strategies for Medication and Mentation process measures (no conclusion).
- There is insufficient evidence for the effect of a specific strategy or specific combination of strategies on What Matters, Medication, Mentation, Mobility or composite 4Ms (no conclusion).
- No study reported results for outcome or structural measures or results based on patient- or system-level factors.

For the effect of AFHS implementation in sites without existing AFHS programming, key findings are:

- There is insufficient evidence to assess the effect of a specific strategy, specific combination of strategies or overall implementation of AFHS on What Matters, Medication, Mentation, Mobility or composite measures of 4Ms (no conclusion).
- A general combination of strategies may improve What Matters, Medication, Mentation, and Mobility process measures over time after AFHS implementation (moderate confidence).
- No study examined outcome or structural measures or results based on patient-level factors. Only 1 study reported results by system-level factors (internal medicine, family medicine, geriatrics), and found geriatric clinics had the largest improvements in 4Ms process measures after implementation of general strategies.

VHA is a leader of AFHS in the US, demonstrating remarkable growth since joining the initiative in March 2020. IHI has actively engaged with VHA, recognizing VHA’s potential to impact a significant population of older adults. The growth of AFHS within VHA has largely been driven by motivated individuals or small teams at various VHA Medical Centers. These champions have used their enthusiasm and expertise to register with IHI, develop plans for 4Ms assessment, and implement measurement of the 4Ms, often without protected time to do so.^26^ While these efforts are commendable, the AFHS mechanism is not yet systematized across the entire VHA, indicating an opportunity for more comprehensive integration.^27^ To scale AFHS in the VHA (and health systems more broadly), there is a need for practical guidance on strategies to implement AFHS and how to select strategies that account for local barriers and facilitators. Although we identified 10 studies that reported data on organizations that implemented AFHS, none of the studies explicitly specified strategies (eg, actor, action, temporality, or dose). This lack of detail makes it challenging to replicate or generalize strategies to health systems that aim to implement AFHS.

Available studies described intensive pre-implementation processes that were used by leadership and implementation teams to identify optimal strategies for their system. Ultimately, selected strategies were tailored to the local context, making direct comparisons across studies a challenge. The included studies employed over 65 implementation strategies, which aligned with all 9 of the Waltz clusters. Most studies included strategies from at least 4 different clusters. The most common strategy clusters were to support clinicians, change infrastructure, or train and educate shareholders. Providing interactive assistance and utilizing financial strategies were least common. Categorizing and assessing the frequency of strategy use by cluster is a helpful framework to organize strategies and offers a picture of where future implementation efforts could focus. Within the “change infrastructure” strategy cluster, numerous studies implemented electronic health record templates to support AFHS implementation. This approach may be more immediately achievable than “utilizing financial strategies”—such as modifying incentive structures—which was attempted in only a single study. As health care systems gather more evidence about both the financial implications and care quality improvements associated with AFHS transformation, they may be positioned to deploy even more wide-reaching strategic approaches.

Overall, it seems that implementation of AFHS strategies may be useful to improve the uptake of 4Ms, though we are unable to make conclusions about the effect of specific strategies on adoption. Additionally, implementation of 4Ms in sites without existing AFHS programming may improve process measures related to the 4Ms. Mostly studies that examined an early and later stage of implementation found an increase in 4Ms process measures over time, which indicates that it may be effective to use some combination of strategies to increase AFHS adoption. However, only 1 study employed a research design to determine the effect of any single strategy on implementation.^25^ Specifically, this study found that using a virtual clinic (simulation training environment to practice 4Ms) or PDSA cycle significantly increased the uptake of AFHS in a health system that had already implemented AFHS. The implementation team identified a virtual clinic or PDSA as promising strategies for their health system following a comprehensive review of data. Therefore, these strategies may not be effective in a system seeking to increase AFHS uptake.

The finding that studies documented AFHS implementation through measures aligning with individual “Ms” is consistent with a focus on the requirements for AFHS recognition as outlined by the IHI. IHI offers sample care plan worksheets, the completion of which is required for level 1 AFHS recognition. Despite the frequent use of specific “M” measures, there was still considerable variation in which measures were employed in the 10 studies (eg, 10 measures to assess Mobility). Standardizing evaluation metrics would enable more meaningful comparisons across health care settings and groups. In addition, few studies reported on outcome measures that are important to health care leadership, clinicians, and patients. There is an opportunity to incorporate more structural and outcome measures in AFHS assessment, and comprehensive evaluation of AFHS implementation requires measures beyond “M”-specific measures. Global measures such as quality of life, home time, and patient and caregiver experience are examples of broad scope measures well matched to AFHS implementation.

Finally, just 1 study^24^ explicitly examined the barriers and facilitators affecting implementation of AFHS, though all 9 other studies reported some contextual factors in the discussion sections of the manuscripts. Barriers and facilitators tended to focus on general topics that could apply to any quality improvement or implementation research topic, such as telehealth limitations, limited time with patients, and documentation challenges, and were not necessarily specific to AFHS implementation. The prospective use of a determinant framework, such as the CFIR 2.0 or the Exploration, Preparation, Implementation, Sustainment (EPIS) framework, would allow for more standardized and comparative assessment of barriers and facilitators across studies and settings.

### Strengths and Limitations of the Evidence Base

The studies in this review have several important limitations. First, many of the studies were conducted as part of quality improvement initiatives. Therefore, the results of these studies may not generalize to other sites, since buy-in, resources, and supports may differ drastically. Second, while all studies described the strategies used, some of the nuanced details of these were not always reported, and fidelity of individual strategy implementation was not assessed. The limited detail on strategies makes it challenging for sites to replicate or adopt the approaches described in the literature. Third, only around half of the measures included across studies aligned with IHI’s standard assessment for assessing Ms, therefore they may not be acceptable to classify it as evidence for 4Ms. However, sites can request to use measures not specified on the IHI care planning worksheets and have this approved by IHI. Fourth, 3 studies reported process or outcome measures only after AFHS implementation. These studies did not report pre-implementation data, so for these studies it is impossible to understand whether AFHS implementation improved measures. Fifth, most studies were not designed to determine the effect of specific implementation strategies on process or outcome measures. Sixth, the large variation across studies in process measures makes cross-study comparisons challenging. In addition, the lack of data on outcome measures presents a major limitation. Seventh, several studies poorly described the process and outcome measures nor was it always clear how measures were constructed. Finally, studies did not always clearly describe the periods of time for which measures were reported.

### Strengths and Limitations of the Systematic Review Process

This review has several strengths and limitations. We employed rigorous search and screening methods for study identification. We used existing frameworks including CFIR 2.0, Waltz strategy clusters, and AHRQ measure categorization to help standardize our analysis of implementation approaches across studies. However, the complexity of the interventions prevented us from quantitatively synthesizing findings or being able to determine the effect of specific strategies on prioritized process and outcome measures. Although grouping strategies into Waltz clusters is a strength, in some cases there may be reasonable disagreement about how strategies were categorized. Related to this, we mapped barriers and facilitators to CFIR 2.0 domains based on the study context. However, given the limited amount of data reported in studies, we may have misclassified some barriers and facilitators by CFIR 2.0 domain. We limited our evaluation to studies that described the use of strategies to implement the AFHS and reported structural, process, or outcome measures. This criterion excluded some studies that described strategies to implement AFHS but only reported educational outcomes. We did not extract data on the pre-implementation process that were often described by studies and that informed the specific implementation strategies. Finally, our requirement that studies implement all 4Ms may have resulted in the exclusion of studies reporting on strategies used to implement individual component Ms of the 4Ms AFHS. Additionally, because it was not clear in all articles whether sites had received AFHS recognition, or were intending to become AFHS recognized, we based our classification of AFHS following the articles’ inclusion of strategies surrounding all 4Ms.

## FUTURE RESEARCH

The evidence base regarding the implementation of AFHS in outpatient settings is small. Future studies should address several gaps in the evidence base. First, there is a need to standardize the measures of AFHS implementation (ie, strategies), which would allow for comparable analyses across settings and populations. Consistent and uniform reporting of strategies would also help sites when planning to implement AFHS into practice. VHA can take the lead in building a detailed registry of implementation strategies, which would provide a valuable foundation to ultimately evaluate the effectiveness of specific strategies. This could be accomplished through qualitative interviews and surveys of sites that have implemented AFHS.

Second, there is a large need for research to examine the effect of specific strategies on implementation and patient outcomes. Such specification, best accomplished through type III hybrid implementation-effectiveness study designs, will be critical to determining and disseminating the most effective implementation strategies. VHA should consider incentivizing Medical Centers to implement AFHS following rigorous implementation science-based approaches so that it is possible to determine the effect of specific strategies on results.

Third, future research, including that in VHA, may benefit from collecting and examining data on pre-implementation to better understand what is needed to prepare for implementation. Additionally, given the potential overlap in contextual factors experienced in other settings, there may be benefit in examining barriers and facilitators of AFHS implementation that have been identified in inpatient, emergency, or other similar settings.^28^ Additionally, prospectively aligning barriers and facilitators with CFIR 2.0 domains and constructs would allow for better targeting of implementation strategies to the needs and strengths of specific organizations..

Fourth, there is a need to improve the measurement of process and outcome measures related to AFHS implementation. Uniform process and outcome reporting would also facilitate cross-study comparisons. In addition, there is a need for global measures of AFHS implementation that go beyond individual Ms reporting to assess quality of life, home days, and patient and caregiver experience. VHA can lead in developing a common measurement set to evaluate process and outcome measures across VA Medical Centers. In this effort, there should be an eye towards measures that can be easily captured using routinely collected data.

Finally, there is a need for studies to examine differences in implementation and patient outcomes based on patient characteristics (eg, race or ethnicity) and system factors (eg, rurality). Sustaining AFHS after dissemination will require a research focus on efficiency, exploring ways to integrate the 4Ms seamlessly into existing workflows and electronic health records.^26^

## CONCLUSIONS

The AFHS movement has rapidly gained momentum, with nearly 5,000 sites recognized. As regulations and incentives increase participation, AFHS transformation requires strategic guidance based on both scientific evidence and pragmatic experience from successful AFHS implementations.

Existing evidence on AFHS implementation strategies in outpatient settings is mostly insufficient to assess the effects of these strategies on implementation or patient outcomes. Nonetheless, using some combination of strategies appears to improve 4Ms process measures. Limitations to available studies underscore the need for more research on AFHS implementation, increased standardization of implementation measures, and greater use of outcome measures that are important to health care leadership, clinicians, and patients.