# RESULTS

## LITERATURE FLOW DIAGRAM

The literature flow diagram summarizing the study selection process is seen below. A full list of excluded studies is provided in Appendix C.

Notes. ^a^We also searched the citations of 13 identified review or systematic review articles (Appendix B).

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; AFHS=Age-Friendly Health System.

The literature flow diagram describes the study selection process. We identified 534 records from Ovid MEDLINE, 1,156 from EMBASE, 204 from CINAHL, 72 from Cochrane Library, and 11 from clinicaltrials.gov. After deduplication there were 1,537 records, and 1,478 were removed during title and abstract screening. We also searched the citations of 13 identified review or systematic review articles. Fifty-nine records remained after title and abstract screening. Of these, 35 were excluded from the review: 11 were excluded for not implementing the 4Ms or not being specific to IHI 4Ms, 7 were excluded for being in the wrong setting/not outpatient, 2 were excluded for having an education-only intervention, 3 were excluded for having no extractable data, 1 was excluded for only being in the pre-implementation phase, 1 was excluded for being a protocol, 6 were excluded for being duplicates, and 4 were excluded for other reasons. After full text review, there were 10 full text articles remaining and 14 conference abstracts.

## OVERVIEW OF INCLUDED STUDIES

Of 1,537 unique records screened, 59 studies met criteria for full-text review. Upon reviewing these, 10 studies were eligible and included for both KQ1 and KQ2.^4,6,17–24^ We also identified 14 conference abstracts that included various degrees of methodological detail and results. While we do not describe these abstracts in this report, details of these abstracts can be found in Appendix F. Reasons for article exclusion at the full-text level included: not implementing the 4Ms framework (N = 11), not in outpatient setting (N = 7), duplicates (N = 6), co-publication or preliminary results (without data for KQ1 or KQ2; N = 4), no extractable data (N = 3), education-only outcomes (N = 2), pre-implementation only (N = 1), and a protocol without results (N = 1).

Appendix G presents study design characteristics. The 10 included studies were conducted in the US between 2015 and 2023 and they were either an NRCS (N = 1),^20^ pre-post (ie, before and after implementation; N = 5), initial implementation phase to a later time point (ie, baseline-later time point; N = 1^i^), or a single group study with data reported at 1 point in time (N = 3).^4,17–19,21–24^ Four studies (1 NRCS^i^, 2 pre-post studies, and 1 post-only study) reported results of strategies implemented at sites with existing AFHS programming (ie, strategies to increase the uptake of AFHS).^6,20–22^ One of these studies reported results before and after implementation of strategies to increase the uptake of AFHS in 2 VA Medical Centers.^6^ Seven studies (5 pre-post studies or baseline-later time point, and 2 post-only studies) reported results for implementation of AFHS strategies at sites that did not already offer AFHS programming. All 10 studies reported patient-level data,^4,6,17–24^ 5 studies also reported provider-level data,^4,6,17,18,21^ and 3 studies also reported health care facility-level data.^20,23,24^ The number of patients in each study varied from 116^18^ to more than 300,000 patients in a multi-facility study.^20^ Eight studies were conducted within primary care or ambulatory care settings, 1 study was conducted in an outpatient cancer center,^23^ and 1 was conducted in convenient care clinics (MinuteClinics).^20^ Appendix H presents baseline characteristics. Only 1 study reported on patient gender, with females representing approximately 61% of patients in this study.^18^ Only 2 studies reported racial/ethnicity data for patients (47.2% to 96% White in 2 studies,^18,24^ 4.2% to 40% Black and 2.7% to 9.2% Hispanic in 1 multi-site study,^24^ and 1% to 3.4% Asian in 2 studies^18,24^).

Figure 1 shows the different ways each of the 4Ms were assessed in the 10 studies. In this figure, measures that are highlighted in blue are part of IHI’s standard assessments for these Ms. Approximately half of the measures used across studies were part of the standard IHI assessments, though this varied across the 4Ms. Of note, sites can request to use measures not specified on the IHI care planning worksheets. Although we required studies implement all 4Ms, 2 studies did not report measures specific to each of the 4Ms.^18,19^ The 10 studies reported 21 different process measures related to the What Matters element. The measures for What Matters included “Advance care planning (ACP) on file or discussed” (N = 5),^17,19,21,22,24^ “Asked ‘what matters’” (N = 6),^4,6,18,20,23,24^, annual wellness exam completion (N = 1),^17^ the CollabRATE questionnaire (N = 1),^20^ or through patient portal messaging (N = 1).^6^ Eight studies included 13 different process measures of the Medication element. Across these studies, Medication was primarily assessed through “review and reconciliation” (N = 5),^4,6,20,22,23^ identification of “high-risk medications” (N = 4),^17,20,21,23^ co-prescription of opioid and sedative-hypnotics (N = 1),^17,24^ and “describe medications” (N = 3).^17,20,23^ Nine studies reported 16 process measures and 3 outcome measures of the Mentation element. In these studies, Mentation was assessed through cognitive (N = 8)^4,6,17,19,20,22–24^ or depression screening (N = 5),^4,6,20,22,23^ caregivers educated and referred to resources (N = 1),^21,24^ dementia counseling (N = 1),^17^ referred to social work (N = 1),^23^ delirium prevented and managed (N = 1),^6^ and diabetes or hypertension control (N = 1).^21^ Nine studies evaluated 11 process measures and 5 outcome measures of the Mobility element. Mobility had the greatest variety of reported measures, with 10 different measures for this M: “fall risk assessed” (N = 5),^17,21–24^ “timed up and go (TUG) test” (N = 3),^20,22,23^ referral to physical therapy (N = 3),^4,17,22^ gait assessment (N = 1),^20^ ADL questions (N = 1),^6^ SARC-F (N = 1),^19^ mobility limitation assessed and managed (N = 1),^6^ mobility goal completed (N = 1),^17^ number of falls (N = 1),^19^ and peripheral neuropathy (N = 1).^23^ Six studies included measures that did not fit into 1 of the 4Ms categories. Of these, 18 were process measures, 2 were outcome measures, and 1 was a structural measure. Three studies included composite measures for completion of all 4Ms, 2 included comprehensive assessments, 1 study included assessments not clearly aligning with any M (the Fatigue, Resistance, Ambulation, Illness, Loss of weight—a 5-component scale for frailty [FRAIL] or the Simplified Nutrition Appetite Questionnaire—assessing appetite loss and risk for weight loss [SNAQ]), and 3 studies included other measures related to the impact of AFHS implementation on practice or capacity.

Figure 1. 4Ms Measures

Notes. Measures that are highlighted in blue are those that IHI includes as part of its standard measures for assessing these Ms. Sites can request to use measures not specified on the IHI care planning worksheets.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; ADL=activities of daily living; ACP=advance care planning; AWV=annual wellness visit; FRAIL=fatigue, resistance, ambulation, illness, loss of weight; PT=physical therapy; SARC-F=strength, assistance with walking, rise from a chair, climb stairs and falls; SNAQ=Simplified Nutrition Appetite Questionnaire.

Figure 1 shows the different way each of the 4Ms were assessed in the 10 studies. Some of these were measures that IHI includes as part of its standard measures for the Ms. The footnote indicates that sites can request to use measures not specified on the IHI care plan worksheet. For “What Matters”, assessments included having an Advanced Care Plan on file or discussed, being asked “What Matters” (part of IHI’s standard assessments), having an Annual Wellness Visit completed, using CollaboRATE (part of IHI’s standard assessments), or patient portal messaging. For Medication, assessments included review and reconciliation of medication, number of high-risk medications, having a co-prescribing of opioid and sedative-hypnotic, and deprescribing medications. All measures were part of IHI’s standard assessments. For Mentation, assessments included cognitive screening, dementia counseling, caregiver education and referral to resources, and depression screening and management (all of which were part of IHI’s standard assessments), as well as referrals to social work, having delirium prevented and managed, diabetes control, and hypertension control. For mobility, assessments included the Timed up and Go test, being referred to physical therapy, neurology, or and aging agency, and having a mobility goal completed (all of which were part of IHI’s standard assessments), as well as fall risk assessment, gait assessment, activities of daily living questions, the SARC-F, having a mobility limitation assessed or managed, number of falls, or peripheral neuropathy. Other measures not falling into any individual 4M category included composite M measures, comprehensive assessments, FRAIL, SNAQ, and other assessments.

## DESCRIPTION OF IMPLEMENTATION SUPPORT STRATEGIES

Table 2 reports the implementation strategies used in each study and the Waltz clusters associated with each strategy. The 10 studies employed 67 implementation strategies, aligning with all 9 of the Waltz clusters. Two studies described 2 different sets of strategies, which are reported separately in Table 2.^6,22^ One study included 20 different strategies in the initial phase of the study and reported most results as a single group, but later used 2 groups of strategies (plan-do-study-act [PDSA] and virtual clinics) and compared these with sites that did not include these strategies.^20^ All 10 studies reported using multiple strategies (mean = 5.6 strategies, range = 2–20) that span multiple Waltz clusters (mean = 4.5 clusters, range = 3–7).

The most commonly used strategy cluster was support clinicians (N = 11).^4,6,17–22,24^ Examples of strategies to support clinicians included providing reminders about the 4Ms through the implementation of templated notes and sharing 4Ms clinical data to support decision-making. Nine studies used the strategy cluster change infrastructure,^4,6,18,20–24^ which included implementation of a templated note into the electronic medical record, revisions to the intake packet, and creating electronic message boards. Eight studies used the strategy cluster train and educate shareholders,^4,18–22,24^ which included training on the 4Ms or infrastructure changes, development of educational support materials, or peer consultations. Seven studies used the strategy cluster evaluative and iterative strategies,^6,18,20–22,24^ which included PDSA, utilizing data dashboards and other forms of performance feedback and tracking, and ongoing process evaluation. Six studies used the strategy cluster engage consumers,^4,18,20,22,23^ which consisted of developed recruitment processes for annual wellness visits or developed pocket cards about the 4Ms to engage patients as active participants in their care. Six studies used the strategy cluster develop shareholder interrelationships,^19–23^ which included the development of interprofessional teams. Four studies used the strategy cluster adapt and tailor to context,^6,20,21^ which included use of data experts or tailoring strategies. Two studies used the strategy cluster provide interactive assistance,^17,^ ^24^ which consisted of using an experienced practice facilitator from a regional quality improvement organization or facilitated tele-video conferencing. Finally, 1 study used financial incentives for the completion of the 4Ms (the strategy cluster utilize financial strategies).^22^

Table 2 Strategies by Waltz Cluster

Study, Year, PMID, Design | Strategies Mentioned | Waltz Clusters^a^
Study, Year, PMID, Design | Strategies Mentioned | Use Evaluative and Iterative Strategies | Provide Interactive Assistance | Adapt and Tailor to Context | Develop Stakeholder Interrelationship | Train and Educate Stakeholders | Support Clinicians | Engage Consumers | Utilize Financial Strategies | Change Infrastructure
Berish, 2023, 36129432, Baseline-later time point^b^ | - Training curriculum with supports; - Facilitated video-teleconferencing and mentorship
Garbarino, 2023, 38038359, Pre-post | - Integration of a tailored EHR note template; - Online learning modules, live trainings; - Team-building exercises, and learning collaborative meetings to track progress; - Establish a patient recruitment process for 4Ms focused annual wellness visits
Guth, 2020, 32976620, Pre-post | - Revision of intake packet; - Initial interdisciplinary comprehensive evaluation; - Risk assignment and high-risk rounds; - Updating high alert medication list and providing customized packets for multi-dose medications
Lundy, 2021, 33275785, Post-only | - Development of rapid geriatric assessment and management program^c^; - Development of interprofessional team; - A rapid assessment to identify 4 common geriatric syndromes; - Education of health professionals to manage treatable causes
Powers, 2022, 36286213-A^d^, Post-only | - Plan-Do-Study-Act cycles with stakeholder clinicians; - Adapt dashboard and review data; - Peer coaching webinars; - Involve clinicians in dashboard development
Powers, 2022, 36286213-B^e^, Post-only | - Incorporation of templated notes in the EMR; - Adapt dashboard and review data; - Involve clinicians in dashboard development
Pohnert, 2023, 36134714^f^, NRCS^g^ and baseline-later time point^b^ | - Professional development^h^; - Practice-based tools^i^; - Infrastructure^j^
Tewary, 2023, 36062563, Pre-post | - Development of interprofessional team; - Conducted needs assessment; - Virtual training; - Infographic development for documentation reinforcement; - Support documents including screenshots of MIPS documentation, performance assessment metrics used by the CMS from the EHR, and educational flyers; - Ongoing process evaluation
Tewary, 2023, 37489318-A^k^, Pre-post | - Comprehensive training on 4Ms; - Conducted needs assessment; - Develop quality improvement team; - Developed a process flow that used an EHR Medicare Preventative Template to facilitate the completion of annual wellness visit components; - Dedicated nurse practitioner for patient contact for annual wellness visits using EHR template; - Templated EHR note
Tewary, 2023, 37489318-B^l^, Post-only | - Comprehensive training on 4Ms; - Develop quality improvement team; - Developed a process flow that used an EHR Medicare Preventative Template to facilitate the completion of annual wellness visit components; - Medical Residents for patient contact for annual wellness visits using EHR template; - Financial incentives to complete 4Ms; - Templated EHR note; - Patient identification through payor lists
Vonnes, 2023, 37783590, Post-only | - Identify stakeholder and develop interprofessional team; - Implementation of screening program
Wismann, 2024, 38488173, Pre-post | - Academic detailing provided by a geriatrician; - Practice facilitation by a trained facilitator from a regional QI organization; - Performance feedback on 6 quality measures mapped to the 4Ms; - EHR support for quality measure reporting and template/workflow changes; - Access to evidence-based clinical support tools and community resource referrals
| Total studies | 7 | 2 | 4 | 6 | 8 | 11 | 6 | 1 | 9

Notes.

a Strategies can fit into multiple clusters

b Initial implementation phase to a later time point

c This study included evidence-based programs to treat sarcopenia and dementia, which were not included in the list of strategies in this table since this activity did not directly support 4Ms implementation

d Tennessee Valley Healthcare System

e McGuire Richmond VAMC

f This study reported initial use of 20 strategies, and later use of a Plan-Do-Study-Act strategy group and Virtual Clinic (A simulation training environment consisting of 3 learning scenarios in which the nurse practitioners could practice integrating the 4Ms and a competency and connections scenario in which the NPs had to make connections among the 4Ms and demonstrate competency integrating the 4Ms into a clinic site) strategy group. We include this as a single group of strategies, as it was not clear which of the initial 20 were included as part of these later 2 strategy groups; Study indicated that 20 strategies were used though extract counts were not able to be determined based on data provided

g Assessed as single-group pre-post for implementation at sites without AFHS

h Orientation, grand rounds, video vignettes, virtual clinic, regional champions, role model video, myth buster communication

i Workflow process map, electronic health record documentation tip sheet, confident conversations, action decision tree, pocket card, chart review directions

j Performance evaluations, alignment with data analytics, senior practice manager virtual huddles, intranet resource, best practice advisory, internal practice newsletter, enterprise newsletter, electronic message board, clinical dashboard

k University clinic

l Health center clinic.

Abbreviations, 4Ms=What Matters, Medication, Mentation, and Mobility; CMS=Centers for Medicare and Medicaid Services; EHR=electronic health record; EMR=electronic medical record; MIPS=Merit-based Incentive Payment System; NRCS=nonrandomized comparative study; QI=quality improvement.

## CONTEXTUAL FACTORS (BARRIERS/FACILITATORS) AFFECTING IMPLEMENTATION OF AFHS PROGRAMMING

One mixed-methods study formally assessed barriers and facilitators affecting AFHS implementation.^24^ This study was conducted in 5 primary care clinics (1 geriatrics clinic, 1 internal medicine clinic, and 3 family medicine clinics) and implemented longitudinal educational outreach visits provided by a geriatrician combined with social marketing, practice facilitation by a trained facilitator from a regional quality improvement organization, performance feedback on 6 quality measures mapped to the 4Ms, EHR support for quality measure reporting and template/workflow changes, and access to evidence-based clinical support tools and community resource referrals. To identify barriers and facilitators impacting AFHS implementation, the authors conducted semi-structured interviews with a practice facilitator, 3 physicians, 1 advanced practice nurse, and 2 registered nurses.

The remaining 9 studies did not formally assess barriers and/or facilitators of the AFHS implementation process, but qualitatively noted barriers and facilitators, largely in the discussion section of the articles. Of the 9 studies, 4 qualitatively reported both barriers and facilitators,^4,17,18,20^ 2 reported barriers only,^22,23^ 1 reported facilitators only,^19^ 1 reported barriers as well as factors that were not clearly categorized as either barriers or facilitators with the text,^21^ and 1 reported only factors that were not clearly categorized as either barriers or facilitators.^6^

Appendix I provides details of the specific barriers and facilitators across the 10 studies. The mixed methods study accounted for 10 of 28 barriers and 8 of 18 facilitators identified across all studies. Individual barriers and facilitators of AFHS implementation were mapped to CFIR 2.0 domains (Table 3; detailed data are provided in Appendix J). The Inner Setting domain, which was considered to be the setting in which AFHS was implemented,^10^ was associated with 28 barriers and facilitators. The Individuals domain, which were the roles and characteristics of individuals,^10^ was associated with 18 barriers and facilitators. The Implementation Process domain, which were the activities and strategies used to implement the innovation,^10^ was associated with 16 barriers and facilitators. The Outer Setting domain, which is the setting within which the Inner Setting exists,^10^ was associated with 4 barriers or facilitators. No study had barriers or facilitators mapped to the Innovation domain.

### Barriers

Twenty unique barriers in 6 studies were mapped to the Inner Setting domain, and included challenges with data collection and documentation^4^; difficulty changing culture, engaging other team members, or establishing new processes^ii^ ^21,^ ^23,^ ^24^; lack of buy-in or 4Ms knowledge^ii^ ^24^; patient preferences^ii^ ^18,^ ^24^; scheduling/time constraints^ii^ ^21,^ ^24^; technology barriers^ii^ ^21,^ ^24^; and other factors (such as reduced training participation due to COVID,^21^ need for clinical support tools, ^ii^ ^24^ access to interpreter services for afterhours visits,^22^ and difficult to implement 4Ms with medically complex or cognitively impaired patients^22^). For the Individual domain, 10 unique barriers (6 studies) included challenges with data collection and documentation^20^; difficulty changing culture, engaging other team members, or establishing new processes^ii^ ^23,^ ^24^; lack of buy-in or 4Ms knowledge^21,^ ^24^; patient preferences^18^; scheduling/time constraints^21^; and factors not categorized elsewhere (eg, access to interpreter services for after-hours visits^22^). Ten unique barriers (7 studies) mapped to the Implementation Process domain included challenges with data collection and documentation^4,^ ^17,^ ^20^; difficulty changing culture, engaging other team members, or establishing new processes^ii^ ^23,^ ^24^; lack of buy in or 4Ms knowledge^20^; patient preferences^18,^ ^22^; and technology barriers.^22^ The Outer Setting domain included 1 barrier (reduced training participation due to COVID^21^) in 1 study.

### Facilitators

Eight unique facilitators (4 studies) were mapped to the Inner Setting domain and included buy-in^ii^ ^24^; administrative support or existing infrastructure^ii^ ^4,^ ^19,^ ^24^; clinical team knowledge of the 4Ms^ii^ ^20,^ ^24^; and other factors (eg, effective user interface design and patient resources^ii^ ^20,^ ^24^). For the Individual domain, 8 unique facilitators (5 studies) included buy-in^ii^ ^17–19,^ ^24^; administrative support or existing infrastructure^ii^ ^19,^ ^24^; and clinical team knowledge of 4Ms.^20^ Six facilitators (3 studies) mapped to the Implementation Process domain were related to administrative support or existing infrastructure^ii^ ^24^; stakeholder partnerships/community support^19,^ ^20^; and factors not classified elsewhere. ^ii^ ^24^ Three unique facilitators (3 studies) mapped to the Outer Setting domain and included stakeholder partnerships/community support^19,^ ^20^ and other factors (eg, patient resources^ii^ ^24^).

### Other Contextual Factors

Two studies reported factors that impacted AFHS implementation, but did not specify whether these were barriers or facilitators.^20,^ ^21^ These included operational policies, provider constraints such as time to chart and AFHS documentation, concerns about infection, limited face-to-face patient visits with providers, and provider engagement with dashboard development.

Table 3 Identified CFIR 2.0 Domains^a^

CFIR 2.0 Domain: | Innovation | Outer Setting | Inner Setting | Individuals | Implementation Process
Count of Unique Barriers
Challenges with data collection and documentation | | | 1^4^ | 1^20^ | 3^4,^ ^17,^ ^20^
Difficulty changing culture, engaging other team members, or establishing new processes | | | 4^b^ ^21,^ ^23,^ ^24^ | 2^b^ ^23,^ ^24^ | 2^b^ ^23,^ ^24^
Lack of buy-in or 4Ms knowledge | | | 1^b^ ^24^ | 3^b^ ^21,^ ^24^ | 1^20^
Patient preferences | | | 3^b^ ^18,^ ^24^ | 2^18^ | 3^18,^ ^22^
Scheduling/time constraints | | | 5^b^ ^21,^ ^24^ | 1^21^
Technology barriers | | | 2^b^ ^21,^ ^24^ | | 1^22^
Other | | 1^21^ | 4^b^ ^21,^ ^22,^ ^24^ | 1^22^
Total unique barriers (studies) | 0 (0) | 1 (1) | 20 (6) | 10 (6) | 10 (7)
Count of Unique Facilitators
Buy-in | | | 1^b^ ^24^ | 5^b^ ^17–19,^ ^24^
Admin support or existing infrastructure | | | 3^b^ ^4,^ ^19,^ ^24^ | 2^b^ ^19,^ ^24^ | 3^b^ ^24^
Clinical team knowledge of 4Ms | | | 2^b^ ^20,^ ^24^ | 1^20^
Stakeholder partnerships/community support | | 2^19,^ ^20^ | | | 2^19,^ ^20^
Other | | 1^b^ ^24^ | 2^b^ ^20,^ ^24^ | | 1^b^ ^24^
Total unique facilitators (studies) | 0 (0) | 3 (3) | 8 (4) | 8 (5) | 6 (3)

Notes.

a Studies could have multiple unique barriers/facilitators for a single row

b Includes factors from the mixed-methods study that formally assessed contextual factors affecting AFHS implementation. Appendix J reports the individual barriers and facilitators details.

## EFFECT OF STRATEGIES TO INCREASE THE UPTAKE OF 4MS IN SITES WITH EXISTING AFHS PROGRAMMING

Table 4 shows the 4 studies in sites that implemented strategies to increase the uptake of AFHS in outpatient sites with existing AFHS programming.^6, 20–22^ One NRCS compared a virtual clinic strategy (simulation training environment to practice 4Ms) and a PDSA strategy to sites that did not implement these strategies. Two studies reported measures before and after (ie, pre-post) implementation of strategies and 1 study only reported results after AFHS strategy implementation without any baseline data. Three studies were conducted in outpatient clinics and 1 study was conducted in multiple convenient care clinics. Two studies included a total of 322 patients,^6,^ ^22^ and 2 studies did not report the number of patients analyzed.^21,20^ One pre-post study also included a second site with only postintervention data on 6 patients.^22^ Two studies reported that they included individuals 65 and older,^21,^ ^22^ and the other 2 studies did not report patient age. No other patient demographic details were provided. Appendix L shows the process measures reported by studies, and no study reported outcome or structural measures. No study reported results based on patient or system-level factors, such as race or ethnicity of patients, or rurality of systems (ie, KQ2B).

Table 4 Study Settings and Comparison

Study | Setting | Comparisons | Measure Reported
Powers, 2022, 36286213 | 2 Veterans Affairs Medical Centers | N/A - post-only | What Matters (P); Medication (P); Mentation (P); Mobility (P); Composite/Other (P)
Tewary, 2023, 36062563 | 3 primary care clinics that partnered with a geriatric workforce enhancement program | Pre vs post implementation | What Matters (P); Medication (P); Mentation (P); Mobility (P)
Tewary, 2023, 37489318 | 2 health care facilities: a university clinic and a health center | University clinic: pre vs post implementation;; Health center: N/A - post-only | What Matters (P); Medication (P); Mentation (P); Mobility (P); Composite/Other (P)
Pohnert, 2023, 36134714 | MinuteClinics | Virtual clinic strategy (simulation training environment to practice 4Ms) and a plan-do-study-act strategy vs sites that did not implement these strategies | Composite/Other (P)

Abbreviations. O=outcome; P=process.

The study with post-only data^6^ and 1 pre-post study^21^ had unclear outcome reporting and eligibility criteria and were considered high risk of bias. The second pre-post study was rated as moderate risk of bias because of substantial attrition.^22^ The NRCS was also rated as moderate risk of bias, primarily due to unclearly defined outcomes.^20^

In summary (Table 5), a general combination of strategies to increase the uptake of AFHS may improve What Matters (low confidence), Mobility (low confidence), and composite 4Ms (moderate confidence) process measures. Studies provide insufficient evidence (no conclusion) for the effect of a specific strategy or specific combination of strategies on the uptake of What Matters, Medication, Mentation, Mobility, or composite 4Ms. Studies also provide insufficient evidence (no conclusion) to assess the effects of a general combination of AFHS strategies on the uptake of Medication and Mentation process measures. No study reported results for outcome or structural measures.

Table 5 Summary of Findings for Strategies to Increase the Uptake of 4Ms in Sites With AFHS^a^

Result | Studies; Design | Methodological Limitations | Indirectness | Imprecision | Inconsistency | Other Issues | Summary | Overall Confidence
What Matters
Process (No outcome or structural measures reported) | 2 pre-post | High^b^ | Direct | Precise | Consistent | N/A | - No conclusion about the effect of a specific strategy or specific combination of strategies. | Insufficient
| | | | | | | - General combination of strategies may improve the uptake of What Matters process measures. | Low Confidence
Medication
Process (No outcome or structural measures reported) | 2 pre-post | High^b^ | Direct | Precise | Inconsistent^c^ | | - No conclusion about the effect of a specific strategy or specific combination of strategies. | Insufficient
| | | | | | | - No difference for general combination of AFHS strategies. | Insufficient
Mentation
Process (No outcome or structural measures reported) | 2 pre-post | High^b^ | Indirect | Precise | Inconsistent^e^ | None | - No conclusion about the effect of a specific strategy or specific combination of strategies. | Insufficient
| | | | | | | - No conclusion for general combination of AFHS strategies may improve Mentation process measures. | Insufficient
Mobility
Process (No outcome or structural measures reported) | 2 pre-post | High^b^ | Direct | Precise | Consistent | None | - No conclusion about the effect of a specific strategy or specific combination of strategies. | Insufficient
| | | | | | | - General combination of AFHS strategies may improve Mobility process measures. | Low Confidence
4Ms Composite
Process (No outcome or structural measures reported) | 1 NRCS and 1 pre-post | Moderate^f^ | Direct | Precise | Consistent | None | - No conclusion about the effect of a specific strategy or specific combination of strategies. | Insufficient
| | | | | | | - General combination of AFHS strategies may improve composite 4Ms process measures. | Moderate Confidence

Notes.

a Only NRCS and pre-post single group studies included

b One was rated as high risk of bias, the other as moderate risk

c One study showed no change since both before and after were at 100% completion, the other reported “improving” but didn’t provide baseline data

d Measures differed and included surrogate measures

e Of the 4 results, 1 showed significant improvement, 2 showed worsening, and 1 showed improvement

f Both moderate risk of bias.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; AFHS=Age-Friendly Health System; NRCS=nonrandomized comparative study.

### What Matters

Three studies (2 pre-post and 1 post-only) at outpatient sites with existing AFHS programming reported What Matters using process measures Appendix K).^6,^ ^21,^ ^22^

Two pre-post studies by the same author (different settings) reported What Matters via documentation of advanced care plans (ACPs). Tewary at al 2023 (PMID 36062563),^21^ which took place at 3 primary care clinics that were partnered with a Geriatric Workforce Enhancement Program (GWEP), found an increase in completion of ACPs 1 year after compared to 1 year before implementation of strategies to increase the uptake of AFHS (20.24% vs 6.79%, p NR). Another study by Tewary 2023 (PMID 37489318),^22^ which took place at 2 health care facilities, found an increase in the proportion of university clinic patients with ACP documentation or refusal during the 4 months after implementing strategies to increase the uptake of AFH compared with the 3 month period before (implementation = 0.97, 95% CI [0.94, 1.00]). Of note, there was a large difference in the number of patients assessed before and after implementation of strategies (146 vs 15 patients). The same study found that 6 of 6 patients had ACP documentation or refusal over a 4-month period in a second site that implemented strategies to increase the uptake of AFHS (pre data NR).

Powers et al’s post-only study reported What Matters after 2 VA Medical Centers implemented strategies to increase the uptake of AFHS.6 They found that 22% of patients had What Matters asked, documented, and acted on in a single patient encounter (no further definition provided) over a 30-day period after 1 Medical Center implemented a templated note to increase the uptake of AFHS). A second VA Medical Center implemented a different set of strategies to increase the uptake of AFHS. In this second site, 15% of patients had What Matters (defined as utilization of patient portal messages) over a 30-day period after implementation of strategies to increase the uptake of AFHS.

### Medications

Three studies (2 pre-post and 1 post-only) at outpatient sites with existing AFHS programming reported process measures of Medication.^6,^ ^21,^ ^22^

#### Medication Review and Reconciliation

The Tewary 2023 (PMID 37489318) pre-post study, which took place at 2 health care facilities, found no significant change in the proportion of university clinic patients whose medications were reviewed and reconciled during a 3-month period after strategies were implemented to increase the uptake of AFHS compared to a 4-month period before implementation (100% completion both periods).^22^ In the same study but at a different site with post-only data, 100% (N = 6) of patients had their medications reviewed and reconciled over a 4-month period after implementation of strategies to increase the uptake of AFHS (pre data NR).

#### High-Risk Medication

Another study by Tewary at al 2023 (PMID 36062563), which took place at 3 primary care clinics that had partnered with a GWEP, found that 3.71% of patients used high-risk medications 1 year after implementation of strategies to increase the uptake of AFHS (pre data NR).^21^ The authors characterized this finding as an “improvement” but did not provide baseline data from prior to AFHS implementation.

Powers et al’s post-only study found that 24% of patients had documentation in the medical record that high-risk medications were reviewed, documented, deprescribed, or avoided in a 30-day period after a VA Medical Center implemented a templated note to increase the uptake of AFHS.^6^ The same study found that in a second VA Medical Center 50% of patients had their medications reviewed and reconciled 30 days after implementation of different strategies to increase the uptake of AFHS.

### Mentation

Three studies (2 pre-post and 1 post-only) at outpatient sites with existing AFHS programming reported on process measures of Mentation.^6,^ ^21,^ ^22^

#### Mental Health or Cognitive Screening

The Tewary 2023 (PMID 37489318) pre-post study, which took place at 2 health care facilities, reported a significant increase in the proportion of university clinic patients who had a depression or cognition screen during a 4-month period after implemented strategies to increase the uptake of AFHS compared to a 3-month period before implementation (risk difference [RD] = 0.59, 95% CI [0.40, 0.77]).^22^ In the same study but at a different site with post-only data, 100% (N = 6) of patients had depression or cognition screening during a 4-month period after implementation of strategies to increase the uptake of AFHS (pre data NR).

Powers et al’s post-only study found that 29% of patients had a cognitive evaluation in a 30-day period after a VA Medical Center implemented a templated note to increase the uptake of AFHS.^6^ The study also found that 24% of patients had a Mini-Cog and PHQ2 in a 30-day period after implementation strategies (not using a templated note) to increase the uptake of AFHS in a different VA Medical Center.

#### Other Mentation Measures

Another pre-post study by Tewary at al 2023 (PMID 36062563), which took place at 3 primary care clinics that had partnered with a GWEP, reported 3 measures of Mentation: proportion of patients with poorly controlled diabetes management, proportion of patients with controlled hypertension, and the proportion of patients provided dementia caregiver education.^21^ This study reported that more patients had poorly controlled diabetes (8.82% vs 22.73%, p NR), and fewer patients had adequately controlled hypertension (78.43% vs 63.24%, p NR) during the year after implementation compared to the year before implementation of strategies to increase the uptake of AFHS. The authors indicated that the poor results after implementation may have been due to the COVID-19 pandemic which caused disruptions in usual care. This same study reported that 1.61% of patients received dementia caregiver education after implementation of strategies. Although this is a low proportion, the authors noted it was an “improvement” from baseline implementation (pre data NR).

### Mobility

Three studies (2 pre-post and 1 post-only) at outpatient sites with existing AFHS programming reported process measures of Mobility.^6,^ ^21,^ ^22^

The Tewary 2023 (PMID 37489318) pre-post study, which took place at 2 health care facilities, assessed Mobility as whether any of the following were present in the medical record: responses to 2 standardized questions regarding falls or injurious falls suffered during the past year, the TUG test, exercise, or physical therapy (PT) referral.^22^ There was a significant increase in patients who had mobility assessed during a 4-month period after implementation of strategies to increase the uptake of AFHS compared to a 3-month period before (100% vs 39%; RD = 0.61, 95% CI [0.53, 0.69]). Notably, the pre period had 146 patients and the post period only had 15. This study also found that 100% (N = 6) of patients had mobility assessed (screening tools, exercise, or referral to PT) after a second clinic implemented strategies to increase the uptake of AFHS (pre data NR).

Another pre-post study by Tewary at al 2023 (PMID 36062563), which took place at 3 primary care clinics that had partnered with a GWEP, found an “improvement” in the proportion of patients receiving a fall risk assessment after compared to before implementation of strategies to increase the uptake of AFHS, though no data was reported for the baseline period (46.72% vs. NR, p NR).^21^

Powers et al’s post-only study found that 24% of patients had documentation in the medical record that a provider reviewed and acted on mobility limitations in a single encounter 30-days after a VA Medical Center implemented a templated note to increase the uptake of AFHS.^6^ The study also found that 54% of patients had mobility assessed through completion of activity of daily living mobility questions in a 30-day period after implementation strategies (not using a templated note) to increase the uptake of AFHS in a different VA Medical Center.

### Composite Measure of 4Ms

Three studies (1 NRCS, 1 pre-post, and 1 post-only) reported composite 4Ms measures.^6,^ ^20,^ ^22^ The Pohnert et al NRCS, which took place in MinuteClinics, found that more 4Ms were completed in sites that used a virtual clinic strategy (incident rate ratio [IRR] = 2.47, 95% CI [1.42, 4.28]) or PDSA strategy (IRR= 3.08, 95% CI [1.19, 7.94]) compared to comparison sites with AFHS.^20^ Powers et al’s post-only study reported that over a 30-day period, 41% of patients had all 4Ms addressed at a VA Medical Center that implemented a templated note as part of their strategy to increase the uptake of AFHS.^6^ The same study found in a VA Medical Center that implemented other strategies only 1% of patients had all 4Ms addressed over a 30-day period .

Tewary 2023 (PMID 37489318), which took place at 2 health care facilities, reported an increase in patients with all 4Ms during a 4-month period after implementation of strategies to increase the uptake of AFHS in a university-based clinic compared to a 3-month period before (RD = 0.85, 95% CI [0.67, 1.02]).^22^ Additionally, the study found 100% (N = 6) of patients had all 4Ms completed during a 4-month period after a health center site implemented strategies to increase the uptake of AFHS.

### Comprehensive Assessment

The Tewary 2023 (PMID 37489318) study, which took place at 2 health care facilities, found that 13.7% of patients had a Medicare preventive template completed (falls, function, PHQ2, mentation, ACP discussion; pre data NR).^22^

## EFFECT OF AFHS IMPLEMENTATION IN SITES WITHOUT EXISTING AFHS PROGRAMMING

Table 6 shows the 7 studies that reported results for outpatient clinics that implemented AFHS at sites that previously did not already offer AFHS programming.

Three studies reported pre-post results,^4,^ ^18,^ ^24^ 2 studies compared a baseline implementation period to a later time point of implementation (ie, baseline-later time point),^17,^ ^20^ and 2 studies reported results at a single time post-intervention (ie, post-only).^19,^ ^23^ In this section, we included data comparing change in results from Pohnert et al (also described above) for sites that did not already have AFHS.^20^ One study took place in 21 federally qualified health centers (FQHCs),^17^ 1 took place in 5 different outpatient settings,^24^ 1 study took place in 1,100 convenient care clinics in 35 states and DC,^17^ 1 study took place at a cancer center,^23^ and 3 studies took place at single clinics.^4,^ ^18,^ ^19^ One very large study included 324,245 patients and the remaining 6 included 19,795 patients (range = 116–6,924). Two studies reported inclusion of patients 65 and older,^19,^ ^24^ and 1 study was not explicit about age but noted that patients were part of a senior oncology program.^23^ Another study reported the patients’ mean age (74.3 years),^17^ and 1 study offered information on the proportion of patients included by age categories, with 25% of patients being less than 70 years old, 32% between 71–75, 25% between 76–80, 11% between 81–85, and 7% greater than 85 years old.^18^ Two studies did not explicitly mention patient age.^4,^ ^20^ Only 2 studies reported patient race or sex (male 39% in 1 study,^18^ Whites 47% to 96% in 2 studies^18,^ ^24^). Seven studies reported process measures, 2 studies reported outcome measures,^19,^ ^23^ 1 study reported structural measures,^20^ and 1 study measures reported another measure (provider knowledge and agreement with site processes).^4^ No study reported results based on patient-level factors, and 1 only study reported results by clinic factor (family medicine, internal medicine, and geriatric clinics).^24^ Because no study adequately defined implementation strategies,^25^ and all included multiple strategies in AFHS implementation, we were unable to report the effect of individual implementation strategies on AFHS measures. We instead report a summary of the impact of AFHS implementation on measures across the studies.

Table 6 Study Settings and Comparison

Study | Setting | Comparisons | Reported Results
Berish, 2023, 36129432 | 21 federally qualified health centers (FQHC)^a^ | Baseline vs later time point | What Matters (P); Medication (P); Mentation (P); Mobility (P)
Garbarino, 2023, 38038359 | A patient centered primary care practice in a northeastern, increasingly urban region of the United States implementing 4Ms in the context of RN-led Medicare annual wellness visits | Pre vs post implementation | What Matters (P); Composite/Other (P)
Guth, 2020, 32976620 | Ambulatory care practice specializing in older adults with medical, medication, and psychosocial needs (MedStar Center for Successful Ageing) | Pre vs post implementation | What Matters (P); Medication (P); Mentation (P); Mobility (P); Composite/Other (P)
Lundy, 2021, 33275785 | Rural primary healthcare system that partnered with a GWEP | N/A – post-only | What Matters (P); Mentation (O); Mobility (O); Composite/Other (O, P)
Pohnert, 2023, 36134714 | Approximately 1,100 MinuteClinics | Baseline vs later time point | What Matters (P); Medication (P); Mentation (P); Mobility (P); Composite/Other (P, S)
Vonnes, 2023, 37783590 | A senior adult oncology program | N/A – post-only | What Matters (P); Medication (P); Mentation (O, P); Mobility (O, P)
Wismann, 2024, 38488173 | Five primary care clinics (1 geriatrics clinic, 1 internal medicine clinic, and 3 family medicine clinics) | Pre vs post implementation | What Matters (P); Medication (P); Mentation (P); Mobility (P)

Notes.

a Three were considered “pilot” sites and 18 other sites implemented strategies at a later date and were considered “comparison” sites.

Abbreviations. GWEP=geriatric workforce enhancement program; O=outcome; P=process; S=structural.

Three pre-post studies had high risk of bias due to uncertainty about completeness of follow-up data (N = 1),^4^ unclear reporting (N = 3),^4,^ ^18,^ ^24^ lack of fully defined outcomes (N = 2),^4,^ ^18^ unclear representativeness of the cohort (N = 1),^4^ and other biases not classified elsewhere (N = 2).^18,^ ^24^ One study that compared baseline implementation to a later timeline of implementation was moderate risk of bias due to lack of fully defined outcomes.^20^ One study that compared a baseline implementation to a later timeline of implementation had no concerns (therefore, low risk of bias).^17^ The 2 studies that reported post-only data had unclear representativeness of the cohort, unclear eligibility criteria, and lack of fully defined outcomes (therefore, high risk of bias).^19,^ ^23^

In summary (Table 7), studies provide insufficient evidence (no conclusion) to assess the effect of a specific strategy, combination of strategies, or overall implementation of AFHS on What Matters, Medication, Mentation, Mobility, or composite measures of 4Ms. Implementation of general strategies may improve What Matters, Medication, Mentation, and Mobility process measures over time after implementation (moderate confidence). No study examined outcome or structural measures.

Table 7 Summary of Findings for AFHS Strategy Implementation in Sites Without AFHS^a^

Result | Studies; Design | Methodological Limitations | Indirectness | Imprecision | Inconsistency | Other Issues | Summary | Overall Confidence
What Matters
Process (No outcome or structural measures reported) | 2 pre-post | High^b^ | Direct | Precise | Inconsistent^c^ | N/A | - No conclusion about the effect of a specific strategy or specific combination of strategies. | Insufficient
| | | | | | | - No conclusion for general combination of AFHS strategies from before to after. | Insufficient
| 2 baseline to later implementation^d^ | Moderate^e^ | Direct | Precise | Consistent | N/A | - Implementation of general strategies may improve What Matters process measures over time. | Moderate
Medication
Process (No outcome or structural measures reported) | 2 pre-post | High^b^ | Direct | Precise | Inconsistent^f^ | N/A | - No conclusion about the effect of a specific strategy or specific combination of strategies. | Insufficient
| | | | | | | - No conclusion for general combination of AFHS strategies. | Insufficient
| 2 baseline to later implementation^d^ | Moderate^e^ | Direct | Precise | N/A | N/A | - Implementation of general strategies may improve Medication process measures over time. | Moderate
Mentation
Process (No outcome or structural measures reported) | 2 pre-post | High^b^ | Direct | Precise | Inconsistent^g^ | N/A | - No conclusion about the effect of a specific strategy or specific combination of strategies, | Insufficient
| | | | | | | - No conclusion for general combination of AFHS strategies. | Insufficient
| 2 baseline to later implementation^d^ | Moderate^e^ | Direct | Precise | Consistent | N/A | - Implementation of general strategies may improve Mentation process measures over time | Moderate
Mobility
Process (No outcome or structural measures reported) | 2 pre-post | High^b^ | Direct | Precise | Inconsistent^h^ | N/A | - No conclusion about the effect of a specific strategy or specific combination of strategies. | Insufficient
| | | | | | | - No conclusion for general combination of AFHS strategies. | Insufficient
| 2 baseline to later implementation^d^ | Moderate^e^ | Direct | Precise | Consistent | N/A | - Implementation of general strategies may improve Mentation process measures over time. | Moderate
4Ms Composite
Process (No outcome or structural measures reported) | 1 baseline to later implementation^d^ | Moderate | Direct | N/A^g^ | N/A^i^ | Only study | No conclusion | Insufficient
Other
Process (No outcome or structural measures reported) | 2 pre-post | High^j^ | Indirect^k^ | Precise | Inconsistent^l^ | N/A | No conclusion | Insufficient

Notes.

a Only NRCS and pre-post single group studies included

b Two rate as moderate risk of bias, 2 as high risk of bias

c Two studies showed improvement, 1 showed mixed results, 1 showed worsening

d Initial implementation phase to a later time point

e One low risk of bias, 1 moderate risk of bias

f One study showed improvement, 2 showed mixed results, 1 showed no difference

g One study showed improvement, 1 showed mixed results, 2 showed no difference

h One study showed no difference, the other showed mixed results

i Only 1 study

j Both rated as high risk of bias

k Measure did not all directly assess AFHS strategies in relation to 4Ms measures, and measure varied

l Mixed results.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; AFHS=Age-Friendly Health System.

### What Matters

Seven studies (3 pre-post, ^4,^ ^24^ ^4,^ ^24^ ^4,^ ^24^ ^4,^ ^27^ 2 from baseline AFHS implementation vs a later time point, and 2 with post-only data) reported different process measures of What Matters.^4,^ ^17–20,^ ^23,^ ^24^ One pre-post study only reported data from a single time point for this measure, so data from this study were not included in the summary of findings table.^18^

#### Pre-Post

Guth et al, which took place in an ambulatory care practice specializing in older adults with medical, medication, and psychosocial needs, reported a significant reduction in the number of patients completing the What Matters question in an intake packet 3 months after compared to 3 months before implementation of AFHS (RD = -0.25, 95% CI [−0.38, −0.11]).^4^ The authors attributed the reduction to a failure to enter intake packet data into the electronic health record, though there was no indication of how this determination was made. This same study found no significant difference in the number of providers who responded that they usually or always discuss What Matters during high-risk rounds after compared to before implementation of AFHS (RD = 0.18, 95% CI [−0.21, 0.58]). Of note, provider data were obtained from a survey of only 11 providers.^4^

Wismann et al, which took place in 5 primary care clinics, reported 2 measures of What Matters.^24^ There was large variation across sites in the documentation of at least 1 “What Matters Most” question in the 2 quarters after compared to 1 to 3 years before (depending on site) implementation of AFHS (range 0% in 1 family medicine site to 30% in a geriatric site). There was also large variation in whether an ACP or surrogate decision maker was documented in the electronic health in the 2 quarters after compared to 1 to 3 years before AFHS implementation (range = 1% in 1 family medicine site to 60% in a geriatric site).

#### Baseline to Later Time Point

Berish et al, which took place at 21 FQHCs, reported increases in the proportion of patients with a new ACP on file (RD = 0.08, 95% CI [0.05, 0.10]) and documentation that an ACP was discussed with patients (RD = 0.18, 95% CI [0.15, 0.22]) 2 years after implementation compared to the first 6 months of implementation at 3 FQHC (ie, pilot sites).^17^ Furthermore, there was no change in the proportion of patients who declined an ACP conversation (0% at both time points). The same study also found that after 18 other FQHCs had implemented AFHS for 4 months, 12% of patients had an annual wellness visit, 2% had a new ACP on file, and 13% had documentation that the ACP was discussed with the patient (pre data NR).

Berish et al also found an increase in the proportion of patients who had a caregiver or care partner identified in the medical record 2 years after implementation compared to the first 6 months of implementation of AFHS in 3 pilot sites (RD = 0.10, 95% CI [0.07, 0.13]).^17^ In addition, 13% of patients had a caregiver or care partner identified in the medical record in 18 additional FQHCs that had only implemented AFHS for 4 months.

Pohnert et al, which took place in approximately 1,100 MinuteClinics, found an increase in the proportion of patients who received What Matters (not defined) nearly 2 years after compared to the first 6 months of implementation of AFHS (24.1% vs 3.4%, p NR).^20^ This study also assessed What Matters using the CollaboRATE questionnaire, which asks patients how much effort was made to help them understand their health issue, how much effort was made to listen to what matters most about their health issue, and how much effort was made to include what matters most in choosing what to do next. Over 75% of respondents aged 65 and older who received care in the system approximately 1 year after AFHS rollout gave the highest score for each question and the overall mean CollaboRATE score was 3.6 on a 4-point scale.

Garbarino et al, which took place at a patient-centered primary care clinic implementing 4Ms during a Medicare annual wellness visit, reported that during the implementation and post-implementation periods, 114 of 116 (98.3%) patients were asked the question “Currently in your life, in 1 or 2 sentences, what matters most to you?” at annual wellness visits led by a registered nurse. The study did not report pre-intervention data for this measure.^18^

#### Post-Only

Lundy et al, which took place at a rural primary health care system that partnered with a GWEP, found that an advanced directive was present for 47.6% of patients 65–74 years old, 66.7% of patients 75–84 years old, and 63.8% of patients 85 years and older either prior to or during the 4-year program supporting AFHS. Vonnes et al^23^ found 18,474 older adults engaged in “What Matters Most” conversations (no denominator was reported) over approximately 3 years after implementing AFHS.^19^

### Medication

Five studies (2 pre-post, 2 baseline intervention vs later time point of intervention, and 1 post-only) reported on Medication measures.^4,^ ^17,^ ^20,^ ^23,^ ^24^ Two studies reported a process measure related to high-risk medication and 3 studies reported other process measures. No study reported outcome or structural measures.

#### High-Risk Medication

##### Pre-Post

Wismann et al, which took place in 5 primary care clinics, reported 2 measures of Medications before and after implementation of AFHS.^24^ The study reported large variation across sites in the proportion of patients concurrently prescribed an opioid and a sedative-hypnotic (benzodiazepine or z-drug) with 2 or more prescriptions in the last 12 months from the 2 quarters after compared to 1 to 3 years before (depending on site) implementation of AFHS (-4% in a geriatric clinic and a family medicine site to 2% in a second family medicine site). Second, the study found large variation in changes in chronic opioid over the last 12-months after (1 to 3 years depending on site) compared to before implementation of AFHS (-10% in an internal medicine site to 3% in a geriatric clinic).

##### Baseline to Later Time Point

Berish et al, which took place at 21 FQHCs, found no significant change in high-risk medication elimination approximately 2 years after compared to the first 6 months of implementation of AFHS in 3 FQHC pilot sites (RD = 0.04, 95% CI [−0.03, 0.12]).^17^ However, this study found a significant increase in opioid misuse mitigation for the same period (RD = 0.18, 95% CI [0.03, 0.34]). In addition, high-risk medications elimination occurred in 63% of patients and opioid misuse mitigation occurred in 86% of patients at 18 other FQHC sites that implemented AFHS for 4 months (pre data NR).

#### Other Measures of Medication

##### Pre-Post

Guth et al reported no change in the proportion of patients who were seen by an onsite pharmacist and completed a medication review 3 months after compared to 3 months before implementation of AFHS (RD = 0.00, 95% CI [−0.12, 0.13], 85% at both time points) at an ambulatory care practice specializing in older adults with medical, medication, and psychosocial needs.^4^ This same study also reported no significant change in the proportion of providers who responded that they usually or always discuss medications during high-risk rounds after compared to before implementation of AFHS (RD = 0.27, 95% CI [−0.06, 0.60]). Again, only 11 providers were surveyed before and after implementation of AFHS.

##### Baseline to Later Time Point

Pohnert et al, which took place at approximately 1,100 MinuteClinics, reported an increase in their measure of Medication (undefined) 2 years after compared to the first 6 months of implementation of AFHS (3.1% vs 21.9%, p NR).^20^

##### Post-Only

The Vonnes et al study, which took place at a senior adult oncology program, found that 80.1% of medication history screens prompted a pharmacy consultation after implementation of AFHS (time period not specified).^23^ In addition, 14% of 1,044 patients received a pharmacy consultation for high-risk medications, including anticoagulants and oral hypoglycemic agents. Finally, it was reported that the pharmacy provided deprescribing consultation for 18.7% of 1,044 patients taking proton pump inhibitors, aspirin for primary prevention, or potentially inappropriate medications.

### Mentation

Six studies (2 pre-post, 2 baseline intervention vs later time point of intervention, and 2 post-only) reported on Mentation measures.^4,^ ^17,^ ^19,^ ^20,^ ^23,^ ^24^ Five studies reported process measures, and 1 study reported an outcome measure.^19^ No study reported structural measures for Mentation.

#### Pre-Post

Guth et al, which took place at an ambulatory care practice specializing in older adults with medical, medication, and psychosocial needs, found no change in the number of patients with a cognitive screen 3 months after compared to 3 months before implementation of AFHS (RD = 0.03, 95% CI [−0.10, 0.16]).^4^ The same study found an increase in the proportion of providers (11 surveyed) that indicated they usually or always discuss Mentation during high-risk rounds after compared to before implementation of AFHS (RD = 0.36, 95% CI [0.02, 0.70]).

Wismann et al, which took place at 5 primary care clinic sites, reported an increase in the proportion of patients screened for cognitive impairment during the 2 quarters after compared to 1 to 3 years (depending on site) before implementation of AFHS (2% increase in a family medicine clinic to 61% increase in a geriatric clinic).^24^ The same study found large variation in the proportion of patients with dementia who received a cognitive assessment after compared to before implementation of AFHS (range = -2% in a family medicine clinic to 77% in a geriatric clinic). Similarly, there was large variation in the proportion of patients with a dementia diagnosis whose caregiver was provided with education and referrals for support after compared to before implementation of AFHS (0% change in 2 family medicine clinics to 21% in a geriatric clinic).

#### Baseline to Later Time Point

Berish et al found no significant change in the proportion of people with dementia receiving monitoring (defined as patients with a diagnosis of Alzheimer’s disease that had a dementia counseling billing claim in the last year) 2 years after compared to the first 6 months of implementation of AFHS in 3 FQHCs (RD = 0.18, 95% CI [−0.19, 0.56]).^17^ The same study found an increase in the proportion of patients receiving a dementia screen 2 years after implementation compared to the first 6 months of implementation of AFHS (RD = 0.24, 95% CI [0.19, 0.28]). Finally, in 18 FQHCs that implemented AFHS, 71% of patients received dementia monitoring and 12% received dementia screening (pre data NR).

Pohnert et al, which took place at approximately 1,100 MinuteClinics, reported an increase in Mentation (not defined) from the initial 6-month period of implementation compared to 2 years after implementation of AFHS (0.8% vs 9%, p NR).^20^

#### Post-Only

Lundy et al found that, in 1,326 patients from a rural primary healthcare system that partnered with a GWEP, 61.7% had normal cognition using the rapid cognitive screen, 17.5% had mild cognitive impairment, and 20.8% screened positive for dementia over 4 years of implementation of AFHS.^19^

Vonnes et al reported 23.6% of patients in a senior adult oncology program screened had an abnormal Mini-Cog score and 8.7% of patients screened positive for depression on the PHQ-2 after implementation of AFHS (time period not reported).^23^ Further, after AFHS strategy implementation, 74.8% of patients with an abnormal cognition screening were referred to pharmacy for medication adherence review, and 36.5% of patients received social work consultations. Approximately 27% of patients were missing results in the mentation screening tool.

### Mobility

Six studies (2 pre-post, 2 baseline intervention vs later time point of intervention, and 2 post-only) reported on Mobility measures.^4,^ ^17,^ ^19,^ ^20,^ ^23,^ ^24^ Five studies reported process measures, and 2 studies reported outcome measures.^19,^ ^23^ No study reported structural measures for Mobility.

#### Fall Risk

##### Pre-Post

Wismann et al, which took place in 5 primary care clinic sites, reported large variation in the proportion of patients with a completed falls risk screening 2 quarters after\compared to the baseline of 1 to 3 years (depending on site) before implementation of AFHS (-2% in a family medicine clinic to 22% in a geriatric clinic).^24^

##### Baseline to Later Time Point

Berish et al reported a significant increase in fall risk management and mobility goal completion 2 years after compared to the first 6 months of implementation at 3 FHQCs (RD = 0.43, 95% CI [0.33, 0.52] and RD = 0.19, 95% CI [0.15, 0.22]).^17^ In addition, 10% of patients had a fall risk management and 9% had mobility goal completion at 18 FQHCs that implemented AFHS at a later time point (no baseline data reported).

##### Post-Only

Lundy et al found that over a 4-year period after implementation of AFHS in a rural primary health care system that partnered with a GWEP, 42.1% of patients screened positive for sarcopenia, which was their measure of mobility.^19^ This same study reported that over 4 years of implementation of AFHS, 32% of patients reported 1 to 3 falls in the last year and 8.6% reported 4 or more falls in the last year.

Vonnes et al found that 96% of patients had a fall risk screening at the time of registration to the senior adult oncology program after implementation of AFHS (time period not specified).^23^ This study also found that 37 patients were missing their TUG assessment at first visit, but the denominator for this number was not clear. Additionally, 21.2% of patients had a baseline TUG >12.0 seconds and 12% of patients had a fall within 1 month of TUG assessment. Finally, 14% of patients had peripheral neuropathy.

#### Other Measures of Mobility

##### Pre-Post

Guth et al reported no significant difference in the number of patients seen by an onsite physical therapist or referred to outpatient physical therapy 3 months after compared to 3 months before implementation of AFHS at an ambulatory care practice specializing in older adults with medical, medication, and psychosocial needs (RD = 0.14, 95% CI [−0.03, 0.31]).^4^ This same study also reported no significant difference in the number of providers (11 surveyed) who responded that they usually or always discuss Mobility during high-risk rounds after compared to before implementation of AFHS (RD = 0.36, 95% CI [−0.02, 0.75]).

##### Baseline to Later Time Point

Pohnert et al reported an increase in Mobility (undefined) over the course of a 2-year period after AFHS strategy implementation at 1,100 MinuteClinics compared to the first 6 months of implementation (2.0% vs 12.4%).^20^

### Composite Measures of 4Ms

Pohnert et al, which took place in approximately 1,100 MinuteClinics, found an improvement in the mean cumulative “M-Score” (the number of “Ms” delivered per visit) 2 years after compared to the first 6 months of implementation of AFHS (mean difference [MD] = 0.62), but did not report on the statistical significance of this change.^20^ The study also reported an increase in the completion of all 4Ms following the implementation of a best practice alert in the electronic health record (<1% vs 5.84%).^20^

### Comprehensive Assessment

Lundy et al reported that 38% of older adults in the target area of a rural primary health care system that partnered with a GWEP were screened with the rapid geriatric assessment being implemented over the 4-year study period.^19^

### Other Results

Four studies (2 pre-post, 1 baseline intervention vs later time point of intervention, and 1 post-only) reported results that did not directly tie to any of the 4Ms but were considered to be related to AFHS implementation.^4,^ ^18–20^

#### Pre-Post

Garbarino et al examined the implementation of the 4Ms in the context of a registered nurse-led Medicare annual wellness visit, though they did not report results for each M individually.^18^ This study reported an increase in the number of registered nurse-led annual wellness visits (19 vs 58) and a decrease in the number of provider-led visits (72 vs 41) from the 5-month period before versus the 5-month period after AFHS strategy implementation. This same study reported an increase in completion of registered nurse-led annual wellness visits from 2020 to 2021 (24 vs 150).

Guth et al reported no difference in the number of providers who reported they usually or always escalate interventions and/or intensity of care (RD = -0.23, 95% CI [−0.63, 0.18]), discuss outcome/impact of prior intervention (RD = 0.09, 95% CI [−0.33, 0.51]), and that high-risk rounds discussions inform and guide care plans (RD = 0.08, 95% CI [−0.35, 0.51]) from before to after AFHS strategy implementation at an ambulatory care practice specializing in older adults with medical, medication, and psychosocial needs.^4^

#### Baseline to Later Time Point

Pohnert et al reported that all 74 regions that were included in AFHS implementation achieved IHI Regional Committed to Care Excellence recognition as part of implementation.^20^

#### Post-Only

Lundy et al reported that 36.5% of patients from a rural primary health care system that partnered with a GWEP screened as frail, 31.3% as pre-frail, and 32.4% as not frail using the FRAIL screening assessment.^19^ The same study reported that 26.1% of patients were at risk for weight loss based on the SNAQ, and the other 73.9% were not at risk.

i The 1 NRCS also included an analysis of baseline-later time point.

ii Indicates barriers and facilitators from the mixed-methods study that formally assessed factors affecting AFHS implementation.