# METHODS

## REGISTRATION AND TOPIC DEVELOPMENT

A protocol for this review was registered on the PROSPERO international prospective register of systematic reviews (CRD42024547851 (https://www.crd.york.ac.uk/PROSPERO/display_record.php?RecordID=547851)). A draft version of this report was reviewed by external peer reviewers; their comments and author responses are located in the Appendix.

Representatives from GEC and a technical expert panel (TEP) were consulted to refine the key questions (KQ). We focused on studies that reported on strategies to implement AFHS in outpatient settings (eg, primary care, convenient care clinics, non-urgent care walk-in clinics, and dental care). We excluded studies that implemented AFHS in emergency departments, urgent care clinics, and outpatient surgical centers. Studies that implemented models of age-friendly care using a definition other than the IHI AFHS definition and those that did not implement all 4Ms were excluded. We developed a conceptual model of our review, which parallels the stages of an implementation research logic model (see Appendix A for the conceptual model).^9^ KQ1 assesses contextual factors (framed as barriers and facilitators) of AFHS implementation (sometimes referred to as "determinants"), categorizing by the updated Consolidated Framework for Implementation Research (CFIR 2.0) domains and constructs.^10^ KQ2a explores the strategies and measures used in AFHS implementation and their effect on process and outcome measures. We initially conceptualized framing KQ2a results using RE-AIM, which targets program elements to help improve adoption and implementation of interventions.^11,12^ However, after reviewing the evidence base we determined that the Agency for Healthcare Research and Quality (AHRQ) Health Care Quality Measure types based on the Donabedian model provides a more helpful framework for contextualizing findings.^13^ Following the AHRQ Measure types, we frame findings based on structural measures (eg, those that indicate capacity to provide care), process measures (eg, what providers do to maintain or improve health), and outcome measures (eg, those that reflect the impact of service on patient health status).^13^ We also consider that patient and system factors may impact structure, process, and outcome measures (KQ2b). While the conceptual model (and a logic model) present stages as a linear process, in practice implementation science is an iterative process and these models can inform not only planning but also the execution and reporting of research.^9^ Our review did not focus on mechanisms of action (ie, how an implementation strategy affects a desired outcome), a stage of the logic model and an area of AFHS implementation that could be explored in future research.

## KEY QUESTIONS

The following KQs were the focus of this review:

Key Question 1 | What are the contextual factors for implementation of AFHS in outpatient settings?
Key Question 2 | 2a. What is the effect of implementation support strategies on process, outcome, and structural measures of AFHS in outpatient settings?^a^; 2b. Do process, outcome, and structural measures differ based on patient or system factors (such as race, ethnicity, or rurality)?^a^

Notes.

a Originally framed as reach, effectiveness, adoption, implementation, and maintenance based on the RE-AIM framework.

Abbreviations. AFHS=age-friendly health system.

## SEARCHING AND STUDY SELECTION

We searched Ovid (Medline), EMBASE, CINAHL, Cochrane, and clinicaltrials.gov from 2015 to March 28, 2024 (see Appendix B for complete search strategies). We used Medical Subject Headings (MeSH) and free text terms specific to age-friendly health care and the 4Ms. We ensured that known relevant publications were captured by our searches. Additional citations were sought from hand-searching reference lists of relevant systematic and non-systematic reviews and consultation with content experts.

Citations were uploaded into EndNote and deduplicated. We screened citations in Systematic Review Data Repository (SRDR+ (https://srdrplus.ahrq.gov/)). To ensure common understanding of the eligibility criteria, we ran a pilot round of 100 citations, where all team members screened the title and abstract of the same citations, and conflicts were resolved as a group. After the pilot round, citations were screened by 2 members of the research team and conflicts were resolved by group discussion. Abstracts accepted at the screening phase underwent full-text review by 2 independent reviewers. In the case of conflicts between reviewers during full text-review, an additional team member was consulted as necessary. A list of excluded studies, along with the reason for their exclusion, can be found in Appendix C.

Study eligibility criteria are listed in Table 1. For both KQ1 and KQ2, eligible studies included adults aged 65 and older, as well as outpatient systems, providers, or staff that serve these individuals. Studies reported on the implementation of AFHS, defined as addressing and acting on each of the 4Ms. We excluded studies implementing age-friendly care other than the IHI AFHS definition or strategies focusing on supporting other models of care, studies not implementing all 4Ms, interventions for students/trainees who are not offering unsupervised patient care, and educational interventions only assessing changes in knowledge or attitudes but not assessing implementation.

Included studies were limited to outpatient care settings, including convenient care clinics, non-urgent care walk-in clinics, or dental settings. Studies were excluded if they took place in urgent care clinics, emergency departments, post-acute care settings, long-term care settings, surgical centers, transitional care settings, or otherwise did not explicitly take place in outpatient, convenient care, or non-urgent care walk-in clinics.

For KQ1, our focus was on reporting the contextual factors, such as barriers and facilitators, affecting implementation of AFHS and eligible records included qualitative or quantitative studies. KQ2 focused on the effect of implementation strategies on system, process, and outcome measures and eligible records included randomized controlled trials (RCTs), non-randomized controlled studies (NRCS), pre-post studies, and single group studies with post-only data.

Table 1 Eligibility Criteria

| Inclusion Criteria | Exclusion Criteria
Population | KQ1 & KQ2: Adults aged 65 and older, or outpatient systems, providers, or staff that serve these individuals
Exposure | KQ1: Implementation of AFHS, defined as assessing and/or acting on each of the 4Ms: What Matters, Medication, Mentation, and Mobility; KQ2: Strategies to support implementation of AFHS | KQ1 & KQ2:; Studies not implementing IHI AFHS; Studies focusing on supporting models of care not self-identified as AFHS; Studies not implementing all 4Ms and/or not addressing and acting on each of the 4Ms; Interventions for students/trainees who are not offering unsupervised patient care; Educational interventions only assessing changes in knowledge or attitudes but do not assess implementation
Comparator | KQ1 & KQ2: Any or no comparator
Outcomes | KQ1:; Implementation Barriers; Implementation Facilitators; Other contextual factors; KQ2:^a^; Structural Measures; Process Measures; Outcomes Measures
Timing | KQ1 & KQ2: Studies published from 2015 forward
Setting | KQ1 & KQ2: Outpatient care settings, including convenient care clinics non-urgent care walk-in clinics, or dental settings | KQ1 & KQ2:; Urgent care clinics; Emergency department; Post-acute care settings; Long-term care settings; Outpatient surgical centers; Transitional care settings (eg, patients transitioning from inpatient to outpatient); Studies that don’t explicitly take place in outpatient, convenient care, or non-urgent care walk-in clinics
Study Design | KQ1 & KQ2:; RCT; NRCS; Single group; KQ 1: Qualitative studies; KQ 2: Statistical process control studies | KQ1 & KQ2:; Non-empirical studies; Case studies or case series focusing on individual patients; Protocols without empirical data; Non-systematic reviews

Notes.

a We originally grouped outcomes following the RE-AIM framework (reach, effectiveness, adoption, and implementation maintenance), but modified the approach to group outcomes following the AHRQ framework.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; AFHS=Age-Friendly Health System; KQ=key question; NRCS=nonrandomized comparative studies.

## DATA EXTRACTION AND RISK OF BIAS ASSESSMENT

We created a data extraction form in SRDR+. For both KQs, we extracted the following data from eligible studies: study design, setting, sample size, and population characteristics at baseline. Free text for qualitative data for KQ1 were extracted in an external table. All data extraction was first completed by 1 reviewer and then confirmed by a second reviewer, with consultation from other team members as needed.

For KQ1, we extracted data on barriers and facilitators related to the implementation of AFHS in outpatient settings. We prioritized extracting quantitative and qualitative results from studies that explicitly analyzed factors affecting implementation. Secondarily, we extracted implementation barriers and facilitators from any section (eg, the Discussion) of all included records. Barriers and facilitators of AFHS implementation were categorized according to the CFIR 2.0.^10^

KQ2 focused on the effect of implementation strategies on structure, process, and outcome measures. We used Waltz’s 9 clusters of strategies^14^ (derived from the original strategies of the Expert Recommendations for Implementing Change [ERIC] project^15^) to categorize the implementation strategies employed in each study. The first stage of the ERIC project used a modified Delphi process to identify 73 distinct implementation strategies. Waltz et al examined the relationship between these strategies and identified 9 strategy clusters.^14^ The 9 strategy clusters include 1) use evaluative and iterative strategies; 2) provide interactive assistance; 3) adapt and tailor to context; 4) develop stakeholder interrelationships; 5) train and educate stakeholders; 6) support clinicians; 7) engage consumers; 8) utilize financial strategies; and 9) change infrastructure (examples of each type provided in Appendix D). To map implementation strategies, data were categorized by 2 team members, and any discrepancies were adjudicated by a third member of the research team. Strategies could fit into multiple Walz clusters. For KQ2 we also extracted data on structure, process, and outcome measures. All results were categorized into AHRQ measure type by 2 team members, and any discrepancies were adjudicated by a third member of the research team.

Study risk of bias was independently assessed by 1 reviewer using questions derived from the Cochrane Risk of Bias tool for RCTs, Critical Appraisal Checklists (CASP) for qualitative studies, and Risk of Bias In Non-randomized Studies – of Intervention tool for other study design (Appendix E). We also evaluated whether each article was free of discrepancies and adequately defined patient eligibility criteria, interventions, and outcomes assessed.

## SYNTHESIS AND CERTAINTY OF EVIDENCE

For KQ1, we synthesized results qualitatively. For KQ2, we assessed the certainty of evidence following the GRADE (Grading of Recommendations Assessment, Development and Evaluation) approach.^16^ Key study findings were used to create evidence profiles, which provide the basis for determination of certainty of evidence and summarize conclusions based on the 4Ms. Within each of the 4Ms categories, we examined results by process, outcome, and structural measures. We considered the study design, the number of studies and participants, methodological limitations, directness of the evidence, precision of the findings, consistency across studies, and other issues. We focused on studies that offered comparative data to inform our conclusions. Certainty of evidence was not assessed for KQ1.