# BACKGROUND

The proportion of the US population aged 65 or older is rapidly growing, with a quarter of the population projected to be over 65 by 2060.^1^ Already, nearly half of Veterans are 65 or older.^2^ At least 80% of older adults have 2 or more chronic medical conditions,^3^ which often require care from multiple clinicians. Because of the complexity of their medical needs, older adults can face fragmented and poorly coordinated care, duplication of services, and harms from unnecessary or inappropriate treatments.^4^

In 2017, the John A. Hartford Foundation, the Institute for Healthcare Improvement (IHI), the American Hospital Association (AHA), and the Catholic Health Association (CHA) of the US jointly launched the Age-Friendly Health System (AFHS) initiative with the goal to improve care and outcomes for older adults. The foundation of AFHS is the “4Ms” framework (What Matters, Medication, Mentation, and Mobility):

- What Matters: Aligning care with patient goals and preferences.
- Medications: Emphasizing age-appropriate medications.
- Mentation: Addressing depression, dementia, and delirium across care settings.
- Mobility: Promoting safe movement to maintain function.

The AFHS initiative has experienced substantial growth over the past decade, with health care organizations across the country implementing AFHS as an intervention to improve care. As of August 2024, nearly 5,000 US health care organizations have received age-friendly recognition. These organizations integrate evidence-based practices, prioritize patient safety, and align care with the preferences of older adults and their caregivers. Many large-scale AFHS adopters are integrated health systems (eg, CVS, Kaiser Permanente).

IHI provides resources to support AFHS implementation, including worksheets, case studies, and return-on-investment analyses. However, the diversity of organizations adopting AFHS—ranging from small physician practices to large integrated health systems—presents a significant implementation challenge.^5,6^ While early AFHS adopters were primarily hospital systems, with most implementation research focused on inpatient settings, AFHS is increasingly being adopted by outpatient and community-based providers. This shift necessitates a better understanding of effective implementation strategies (ie, actions taken to enhance adoption such as modifying recording systems or conducting education sessions).

AFHS implementation can be studied using different research designs (eg, effectiveness-implementation hybrid designs or multiphase optimization strategies^7,8^). Such studies may use process measures (eg, proportion of patients screened for depression, fidelity to intervention protocols), structural measures (eg, number of sites recognized as age-friendly), and outcome measures (eg, number of patient falls) to characterize AFHS implementation, reach, and impacts.

The Veterans Health Administration (VHA) Office of Geriatrics and Extended Care (GEC) has established the goal that every Veteran receive AFHS care at every encounter. To this end, VHA joined the AFHS initiative in March 2020. GEC leads Action Communities that provide monthly webinars and coaching calls to foster a community of practice within VHA, enabling health care providers across various settings to champion the 4Ms. As of May 2024, 364 care settings at 151 VHA facilities have earned recognition from IHI, and VHA is on track to become the largest integrated AFHS in the US.

In mid-2025, VHA Health Systems Research (HSR) will convene a State-of-the-Art (SOTA) Conference on AFHS care. The SOTA will focus on barriers and facilitators to AFHS dissemination and sustainment, and define an agenda for future VA research on AFHS care. This systematic review synthesizes available evidence on the implementation of AFHS in outpatient settings to inform the upcoming SOTA and GEC’s efforts to implement AFHS across the VHA.