# APPENDIX M PEER REVIEW COMMENTS AND RESPONSES

Comment # | Reviewer # | Comment | Author Response
Are the objectives, scope, and methods for this review clearly described?
1 | 1 | Yes | Thank you.
1 | 2 | Yes | Thank you.
1 | 3 | Yes | Thank you.
1 | 4 | Yes | Thank you.
1 | 5 | Yes | Thank you.
Is there any indication of bias in our synthesis of the evidence?
2 | 1 | No | Thank you.
2 | 2 | No | Thank you.
2 | 3 | No | Thank you.
2 | 4 | No | Thank you.
2 | 5 | No | Thank you.
Are you aware of any [underlined: published] or [underlined: unpublished] studies that we may have overlooked?
3 | 1 | No | Thank you.
3 | 2 | No | Thank you.
3 | 3 | No | Thank you.
3 | 4 | Yes - See comments; some relevant studies excluded | Thank you. We have addressed your comments below.
3 | 5 | No | Thank you.
Additional suggestions or comments can be provided below. If applicable, please indicate the page and line numbers from the draft report.
4 | 1 | [No comments provided] | Thank you for your review.
4 | 2 | Thank you for the opportunity to review the final document “Implementation of Age-Friendly Health Systems in Outpatient Settings: A Systematic Review.” The document is impressive and will move the AFHS movement forward in important ways. I have some minor suggestions for clarity and consistency (e.g with IHI language).; The Key findings section was a bit confusing with language. Suggest clarification of what is a process, outcome, structural measure; Example: “A general combination of strategies may improve What Matters, Medication, Mentation, and Mobility process measures over time after AFHS implementation (moderate confidence).” | Thank you. We added the following text to the Methods section of the Executive Summary to clarify the definition of process, outcome, structural measures in this report:; Executive summary: For KQ 2 we analyzed the effect of implementation strategies on process (eg, proportion of patients screened for depression, fidelity to intervention protocols), outcome (eg, number of patient falls), and structural measures (eg, number of sites recognized as Age-Friendly) based on the Agency for Healthcare Research and Quality’s Health Care Quality Measure categorization.; Methods: Following the AHRQ Measure types we frame findings based on structural measures (eg, those that indicate capacity to provide care), process measures (eg, what providers do to maintain or improve health), and outcome measures (eg, those that reflect the impact of service on patient health status).
5 | 2 | What is meant by sites with and without AFHS? Note that the content under these headers both include strategies..but titles are different.; Effect of AFHS Strategies to Increase Uptake of 4Ms in Sites with AFHS; Effect of AFHS Implementation in Sites Without AFHS | Thank you. The sections differentiate between studies in sites with existing AFHS programming at the time of strategy implementation verses sites that were implementing AFHS into a setting without existing AFHS programming.; We have updated these titles in the Executive Summary and Main Document to say:; Effect of Strategies to Increase the Uptake of 4Ms in Sites with Existing AFHS Programming; Effect of AFHS Implementation in Sites Without Existing AFHS Programming
6 | 2 | Page vi: Line 17: Need to add “age 65 and older” as currently states “every Veteran” | Thank you. We have added this text.
7 | 2 | Page vi: Line 30: suggest using “framework” and not “model” to be consistent with the IHI guidebooks | Thank you. We have updated the language here and throughout as appropriate.
8 | 2 | Line 48: same as line 30 – consider this change throughout the document. | Thank you. We have updated the language here and throughout as appropriate.
9 | 2 | Page viii: line27; Consider defining “sites with AFHS” or clarify header and sites with out AFHS. I am not clear on how there can be a site without AFHS studied in line 59 on page viii, it states those without AFHS programing. Not sure what this means. | Thank you. These refer to the difference between studies of sites with existing AFHS programming at the time of strategy implementation versus sites that were implementing AFHS into a setting without existing AFHS programming.; We have updated these titles in the Executive Summary and Main Document to say:; Effect of Strategies to Increase the Uptake of 4Ms in Sites with Existing AFHS Programming; Effect of AFHS Implementation in Sites Without Existing AFHS Programming
10 | 2 | Consider clarifying early on process measure definition. Assuming this is the count of the 4Ms documented? Same with structural measures. These are defined on page 4. | Thank you. We added the following text to the Methods section of the Executive Summary:; Executive summary: For KQ 2 we analyzed the effect of implementation strategies on process (eg, proportion of patients screened for depression, fidelity to intervention protocols), outcome (eg, number of patient falls), and structural measures (eg, number of sites recognized as Age-Friendly) based on the Agency for Healthcare Research and Quality’s Health Care Quality Measure categorization.; Methods: Following the AHRQ Measure types we frame findings based on structural measures (eg, those that indicate capacity to provide care), process measures (eg, what providers do to maintain or improve health), and outcome measures (eg, those that reflect the impact of service on patient health status).
11 | 2 | Main Document; Recommendations: Consider VHA capture pre-implementation processes across VHA to understand what is needed to prepare for implementation. The pre-implementation process maybe just as important as strategies. | Thank you for this recommendation. We agree that VHA would benefit from capturing pre-implementation processes, including needs assessment, assessment of barriers and facilitators, and determination of fit to context prior to AFHS implementation. We have amended the discussion section of the report to state the following:; Third, future research, including that in VHA, may benefit from collecting and examining data on pre-implementation to better understand what is needed to prepare for implementation.
12 | 2 | Main Document; Page 33 line 3. The statement does not reflect current recommended practice of aligning implementation strategies with local barriers and facilitators “replicable guidance on the strategies they should use to implement the AFHS model.” But I do agree with your recommendation to specify details about strategies (e.g., actor, action, temporality, or dose). | Thank you and we agree. Our intent was to emphasize the need for standardization of the strategies facilities/organizations may consider but appreciate your comment that there needs to be consideration for the local context. We have edited this sentence to say:; To scale AFHS in the VHA (and health systems more broadly) there is a need for practical guidance on strategies to implement AFHS and how to select strategies that account for local barriers and facilitators.
13 | 2 | For the complete document:; Make sure to refer to the 4Ms (not 4M- per IHI guidelines) (Note this suggestion throughout the complete document). | Thank you. We have made this correction throughout.
14 | 2 | For the complete document:; Suggest using “framework” and not “model” to be consistent with the IHI guidebooks | Thank you. We have updated the language throughout as appropriate.
4 | 3 | [No comments provided] | Thank you for your review.
4 | 4 | Thank you for the opportunity to review this evidence synthesis. Overall, it is rigorous and does a strong job of refluxing the (unfortunately) limited evidence on the key questions. My suggestions for revision are as follows:; (1) The conceptual relationship between AFHS and 4Ms as used in the review is confusing and shifts throughout the piece. Could a paper (and its underlying study setting) be classified an AFHS without having implemented the 4Ms? If a study included 4Ms process measures then isn’t this by definition an AFHS? I might suggest that the piece defines an AFHS as a study site that has declared the intention to become AF, as defined as the specific intention to implement the 4Ms as a set of care processes. Then those that have begun 4Ms implementation are those that have started the AFHS transformation journey vs those who have not (which is then later used to divide studies). | Thank you for this comment. For this review, we only included studies that implemented all 4Ms of AFHS (aligning with the IHI definition of AFHS as a set of all 4Ms). To your comment, yes, it is possible that a site could be recognized as an AFHS (level 1) by developing a plan for future AFHS implementation but not yet implementing AFHS. These sites would not have been captured in our review. Unfortunately, since not all studies stated whether their sites had received level 1 (ie, completed planning worksheets to implement AFHS), were further along the AFHS transformation journey, or had achieved level 2 AFHS recognition (collecting at least three months of data on AFHS implementation with older adults), we were not able to specifically state this in the report.; We have amended the discussion to address this:; Finally, our requirement that studies implement all 4Ms may have resulted in the exclusion of studies reporting on strategies used to implement individual component Ms of the 4Ms AFHS. Additionally, because it was not clear in all articles whether sites had received AFHS recognition, or were intending to become AFHS recognized, we based our classification of AFHS following the articles’ inclusion of strategies surrounding all 4Ms.
5 | 4 | (2) Similarly I struggled to conceptually understand the relationship between contextual factors, facilitators and barriers, implementation support strategies, and patient and system factors (as defined across the different key questions). Please add a conceptual model showing how these concepts relate to each other and to the concept of AFHS and implementation of the 4Ms as resolved in response to (1) above (and also as part of addressing (3 – 2a below). | Thank you for this recommendation. We now include a conceptual model for these concepts that mirrors an implementation research logic model.; In addition, we now categorize the barriers and facilitators in KQ1 by CFIR 2.0. The newly added Table 3 and Appendix I support this text.
6 | 4 | (3) Relatedly I struggled to understand KQs 2a and 2b as stated. Re: 2a – as explained more fully in (4) below, the 4Ms is a set of process measures and therefore being an AFHS is, by definition, measured by adherence to a set of process measures. Given this, I struggled to understand how a structural measure or outcome measure (by itself) can measure whether an AFHS implementation support strategy was successful. Again, this could likely be clarified by a conceptual model that explains how these different concepts relate. | Based on the IHI definition, we discuss the 4Ms as a framework, not exclusively a set of process measures. Process measures (often implementation outcomes) are upstream measures of implementation success, whereas outcome and structural measures may be downstream measures of success, often assessed as part of “effectiveness” in hybrid implementation-effectiveness trials. One of our recommendations emerging from this review is the need for more study designs of this nature to jointly assess implementation and effectiveness outcomes.; We have added more information about how we defined process, outcome, and structural measures in the executive summary for earlier clarification of this.
7 | 4 | Re: 2b - What does it mean to have “differences in measures”? The measures themselves are different across the sets of studies (Independent variables? Dependent variables?) or the values/impacts are different when the measures are the same? Or something else? I think rewording this question to improve clarity is essential. | Thank you. We have reworded this question to:; Do process, outcome, and structural measures differ based on patient or system factors (such as race, ethnicity, or rurality)?
8 | 4 | (4) One of the key takeaways is that there is not a standard definition of AFHS (or the 4Ms?) used in the literature. This is problematic as it means that even the 10 articles are not necessarily supporting evidence of a consistent “intervention”. Given that IHI has put out a standard set of assessment and act on care processes that define each M, it is critical to add, for each article, an assessment of the extent to which it addressed this set of care processes. Notably, ACP documentation is not considered to constitute addressing What Matters. Thus, if an article is focused on this for WM, it may not be acceptable to classify it as evidence for 4Ms. Ultimately I think it is ok to leave as is as long as there is a clear table in the main body of the report that aligns with the IHI set of care processes so that the evidence can be interpreted with this in mind. | Thank you. We actually felt that studies were clear in their definition of AFHS and the 4Ms, aligning with the IHI definition. We had difficulty determining where sites were in the implementation trajectory, as not all studies specified whether they had achieved level 1 or level 2 AFHS recognition. We appreciate your recommendation to show how the M measures align with the IHI care processes described in their care planning worksheets and have updated Figure 2 to better show this alignment, and we have added a small summary statement to the results sections:; Figure 1 shows the different ways each of the 4Ms were assessed in the 10 studies. In this figure, measures that are highlighted in blue are part of IHI’s standard assessments for these Ms. Approximately half of the measures used across studies were part of the standard IHI assessments, though this varied across the 4Ms. Of note, sites can request to use measures not specified on the IHI care planning worksheets.; In the discussion, we list this as a limitation, but also acknowledge that sites can request to use measures not specified on the IHI care planning worksheets and have this approved by IHI.; Third, only around half of the measures included across studies aligned with IHI’s standard assessment for assessing Ms, therefore they may not be acceptable to classify it as evidence for 4Ms. However, sites can request to use measures not specified on the IHI care planning worksheets and have this approved by IHI.
9 | 4 | (4a) A more minor but related point. The piece states (page 10 line 47) “Studies reported on the implementation of AFHS (had to act on all “4Ms”).” This suggests that an inclusion criterion was that all 4Ms were not just assessed but acted upon. I saw no evidence that this was used to screen articles in the rest of the methods and the actual articles described also did not seem to fit this criterion. Please either remove or clarify. | Thank you for this careful attention to language and request for clarity. We have modified this sentence to read “Studies reported on the implementation of AFHS (had to assess or act on all “4Ms”).”
10 | 4 | (5) While I know it is traditional in an evidence review not to describe each article in the main body of the report, given that there are only 10, it would help the clarity and interpret ability immensely if you could start the results by summarizing each article - setting, study design, key outcomes. As a reader I had to do a lot of cross referencing and piecing together as I moved through the sections trying to remember what a given article was about and therefore how it supported the given evidence subdomain. As part of this, I would also consider shifting from using authors names to a short description (eg “in the Minute Clinic study” in much more helpful). | Thank you for these suggestions. We have added a table at the beginning to each of the subsections of the results that discuss the effect of strategies to increase uptake of 4Ms in sites with existing AFHS programming and the effect of AFHS implementation in sites without existing AFHS programming. These tables provide a brief description of the study settings, and the comparisons examined in the outcomes. We also added additional text to each of these sections providing more description of the studies.
11 | 4 | While likely out of scope (especially at this point), there is additional evidence that could be garnered from expanding to allow broader settings beyond only ambulatory to be included. Many of the same issues related to AFHS implementation extend across settings and may therefore facilitate stronger conclusions to inform action. Indeed the whole premise of AFHS is that efforts are at the health system level and not focused only on one setting. I will specifically point to a paper directly on AFHS implementation barriers and facilitators than seems on point for inclusion but was excluded: https://pubmed.ncbi.nlm.nih.gov/37246845/ | We agree that studying implementation of AFHS across all settings is important, but yes, this was beyond the scope of this review. The paper cited was excluded at the full text review stage due to having 21 of 29 interviews occurring in inpatient settings.; However, we have added the following text to the discussion section to address your concern:; Third, future research, including that in VHA, may benefit from collecting and examining data on pre-implementation to better understand what is needed to prepare for implementation. Additionally, given the potential overlap in contextual factors experienced in other settings, there may be benefit in examining barriers and facilitators of AFHS implementation that have been identified in inpatient, emergency, or other similar settings.^28^
4 | 5 | Minor editorial comments:; Page vi, Line 15: Veterans Health Administration does not need to be plural. | Thank you. We have made this correction.
5 | 5 | Page ix, Line 29: “VHA has emerged as the nation’s largest AFHS community...” Technically, there are more CVS minute clinics recognized than VHA settings. I would change this line to “VHA has emerged as a leader of AFHS in the US, demonstrating ...” Also repeated in line 33 on page 34. | Thank you. We have adjusted this language in both places.
6 | 5 | Page x, Line 39: duplicate use of “evidence.” Can delete repeated word. | Thank you. We have made this correction.
7 | 5 | Page 13, Figure 1: I would consider naming “4Ms Process Measures”. Recommend flipping Mobility and Mentation so that Mentation comes after Medication so that the 4Ms are listed in order (What Matters, Medication, Mentation, Mobility, Other). | Thank you. Some of measures listed in this figure are outcome measures, so we have left this title as “4Ms Measures”. We have moved the order of these per your suggestion.
8 | 5 | Page 35, line 11: Change “Age-Friendly Hospital measures” to “Age-Friendly Hospital Measure”. Measure is singular and capitalized. | Thank you. We have made this correction.