# APPENDIX L AHRQ MEASURES REPORTED BY STUDY DESIGN

| What Matters- Process | What Matters- Outcome | What Matters- Structural | Medication- Process | Medication- Outcome | Medication- Structural | Mentation-Process | Mentation- Outcome | Mentation- Structural | Mobility- Process | Mobility- Outcome | Mobility- Structural | Other- Process | Other- Outcome | Other- Structural
NRCS
Pohnert, 2023, 36134714
Single Group With Multiple Time Points
Berish, 2023, 36129432
Garbarino, 2023, 38038359
Guth, 2020, 32976620
Tewary, 2023, 36062563
Tewary, 2023, 37489318-A^a^
Wismann, 2024, 38488173
Single Group Without Data for Comparison
Lundy, 2021, 33275785
Powers, 2022, 36286213- A^b^
Powers, 2022, 36286213-B^c^
Tewary, 2023, 37489318-B^d^
Vonnes, 2023, 37783590

Notes.

a University Clinic site

b Tennessee Valley Healthcare System site

c McGuire Richmond VAMCbsite

d Health Center Clinic site.