# APPENDIX K RESULTS OF IMPLEMENTATION STRATEGIES (KQ2)

## K1. What Matters

Author, Year, PMID, Study Design | Details | Population | Follow-Up | Groups/Comparators | N/N (%) | Effect Size (95% CI), Reported P Value/ Absolute Difference
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Annual Wellness Visit completion; Advanced Care Planning (ACP) (new on file) | All | June 2020-Jan 2022 | Baseline 3 Pilot 4Ms sites | 9/337 (3%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Annual Wellness Visit completion; Advanced Care Planning (ACP) (new on file) | All | June 2020-Jan 2022 | 3 Pilot 4Ms sites | 97/397 (24%) | RD 0.22 (0.17, 0.26)^c^ | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Annual Wellness Visit completion; Advanced Care Planning (ACP) (new on file) | All | June 2020-Jan 2022 | 18 comparison sites | 815/6527(12%) | - | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | | All | June 2020-Jan 2022 | Baseline 3 Pilot 4Ms sites | 1/337 (0%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | | All | June 2020-Jan 2022 | 3 Pilot 4Ms sites | 31/397 (8%) | RD 0.08 (0.05, 0.10)^c^ | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | | All | June 2020-Jan 2022 | 18 comparison sites | 131/6527 (2%) | - | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | ACP (discussed with patient [advance care plan conversation documented]) | All | June 2020-Jan 2022 | Baseline 3 Pilot 4Ms sites | 0/337 (0%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | ACP (discussed with patient [advance care plan conversation documented]) | All | June 2020-Jan 2022 | 3 Pilot 4Ms sites | 73/397 (18%) | RD 0.18 (0.15, 0.22),^c^ p = 0.000 | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | ACP (discussed with patient [advance care plan conversation documented]) | All | June 2020-Jan 2022 | 18 comparison sites | 849/6527 (13%) | - | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | ACP (patient declined [those who refused an advance care plan conversation]) | All | June 2020-Jan 2022 | Baseline 3 Pilot 4Ms sites | 0/337 (0%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | ACP (patient declined [those who refused an advance care plan conversation]) | All | June 2020-Jan 2022 | 3 Pilot 4Ms sites | 1/397 (0%) | RD 0.00 (0.00, 0.01),^c^ p = 0.317 | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | ACP (patient declined [those who refused an advance care plan conversation]) | All | June 2020-Jan 2022 | 18 comparison sites | 0/6527 (0%) | - | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Caregiver/ Care partner identification | All | Jan 2021-Jan 2022 | Baseline 3 Pilot 4Ms sites | 4/328 (1 %) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Caregiver/ Care partner identification | All | Jan 2021-Jan 2022 | 3 Pilot 4Ms sites | 44/397 (11%) | RD 0.10 (0.07, 0.13) | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Caregiver/ Care partner identification | All | Jan 2021-Jan 2022 | 18 comparison sites | 849/6527 (13%) | - | Process
Garbarino, 2023, 38038359, Single group (Pre-post) | Patients responding to “What Matters” questions | Patients scheduled for an RN-led AWV | At follow-up (2021) | Patients scheduled for an RN-led AWV | 114/116 (98.3%) | - | Process
Garbarino, 2023, 38038359, Single group (Pre-post) | Asked the “what matters” question: “Currently in your life, in one or two sentences, what matters most to you?” | Patients receiving AWV | At AWV | RN-led AWV | 116 | - | Process
Guth, 2020, 32976620, Single | “Usually” or “Always” discussing 4Ms during high-risk rounds (provider reported) - Matters | Providers | Pre- vs. post-implementation (Oct-Dec 2018 vs Jan-Mar 2019) | Pre-intervention | 6/11 (54.5%) | | Process
Guth, 2020, 32976620, Single | “Usually” or “Always” discussing 4Ms during high-risk rounds (provider reported) - Matters | Providers | Pre- vs. post-implementation (Oct-Dec 2018 vs Jan-Mar 2019) | Post intervention | 8/11 (72.7%) | RD 0.18 (−0.21, 0.58)^c^ | Process
Guth, 2020, 32976620, Single group (Pre-post) | What matters: Patient completed the “what matters” question in the intake packet, which asks them to choose an item that is most important to them regarding their medical care. | Snapshot of patients before training in 4Ms and after | Pre- vs. post-implementation (Oct-Dec 2018 vs Jan-Mar 2019) | Pre-implementation | 63/67 (94%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | What matters: Patient completed the “what matters” question in the intake packet, which asks them to choose an item that is most important to them regarding their medical care. | Snapshot of patients before training in 4Ms and after | Pre- vs. post-implementation (Oct-Dec 2018 vs Jan-Mar 2019) | Post-implementation | 38/55 (69%) | RD−0.25 (−0.38, −0.11)^c^ | Process
Lundy, 2021, 33275785, Single group (Post only) | Had advanced directive completed prior to or during the program | 65–74 years old | At assessment | Patients receiving a rapid geriatric assessment (RGA) | NR/NR (47.6%) | - | Process
Lundy, 2021, 33275785, Single group (Post only) | Had advanced directive completed prior to or during the program | 75–84 years old | At assessment | Patients receiving a rapid geriatric assessment (RGA) | NR/NR (66.7%) | - | Process
Lundy, 2021, 33275785, Single group (Post only) | Had advanced directive completed prior to or during the program | >=85 years old | At assessment | Patients receiving a rapid geriatric assessment (RGA) | NR/NR (63.8%) | - | Process
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “What Matters” | Eligible patients completing 4Ms | First 8 months vs February 2022 | First 8 months | 3.4% | | Process
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “What Matters” | Eligible patients completing 4Ms | First 8 months vs February 2022 | Following best practice alert | 18.2% | 14.8% | Process
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “What Matters” | Eligible patients completing 4Ms | First 8 months vs February 2022 | February 2022 | 24.1% | 20.7% | Process
Pohnert, 2023, 36134714, NRCS^d^ | Respondents giving the highest score on the CollaboRATE questionnaire-How much effort was made to help you understand your health issues? | Eligible patients completing 4Ms | Follow-up (Year 2) | Adults aged 65 and older that received care in the system in 2021 | 75.6% | - | Process
Pohnert, 2023, 36134714, NRCS^d^ | Respondents giving the highest score on the CollaboRATE questionnaire-How much effort was made to listen to what matters most to you about your health issues? | Eligible patients completing 4Ms | Follow-up (Year 2) | Adults aged 65 and older that received care in the system in 2021 | 77.6% | - | Process
Pohnert, 2023, 36134714, NRCS^d^ | Respondents giving the highest score on the CollaboRATE questionnaire-How much effort was made to include what matters most to you in choosing what to do next? | Eligible patients completing 4Ms | Follow-up (Year 2) | Adults aged 65 and older that received care in the system in 2021 | 76.2% | - | Process
Pohnert, 2023, 36134714, NRCS^d^ | Mean CollaboRATE score (on a 4-point scale) | Eligible patients completing 4Ms | Follow-up (Year 2) | Adults aged 65 and older that received care in the system in 2021 | 3.6 | - | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | Health Factor Addressed (What Matters)- Patient portal messages (proxy for engagement); or; What Matters is asked and documented, and care plan is aligned with their health outcome goals and care preferences | All | During 30-day period | GeriPACT Non-Templated Notes | 19/127 (15%) | - | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | | All | During 30-day period | GeriPACT and HBPC Templated Notes | 11/49 (22%) | | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Matters Most—ACP documentation or refusal | All | Oct-Dec 2021 | University Clinic- Needs Assessment | 5/146 (3.4%) | | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Matters Most—ACP documentation or refusal | All | Sep-Dec 2022 | University Clinic- After QI Implementation | 15/15 (100%) | RD 0.97 (0.94, 1.00)^1^ | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Matters Most—ACP documentation or refusal | All | Dec 2022-Mar 2023 | Health Center- After QI Implementation | 6/6 (100%) | - | Process
Tewary, 2023, 36062563, Single group (Pre-post) | Advance Care Plan | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Baseline (2019) | 6.79% | | Process
| | | | Year 1 (2020) | 20.24% (Improving) | 13.45%
Vonnes, 2023, 37783590, Single group (Post only) | Older adults engaged in What Matters Most conversations in the Senior Adult Program since program implementation | All | Since 2019 | Geriatric oncology patients | 18,474 | - | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Baseline | 0/725 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (30%) | 30% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Baseline | 0/1441 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (3%) | 3% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Baseline | 0/1703 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (5%) | 5% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Baseline | 0/1386 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (1%) | 1% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Baseline | 0/552 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | At least one “What Matters Most” question documented in the EHR | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (0%) | 0% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Baseline | ~44/^1^725 (6%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (66%) | 60% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Baseline | ~86^1^/1441 (6%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (26%) | 20% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Baseline | ~443^1^/1703 (9%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (26%) | 17% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Baseline | ~360^1^/1386 (26%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (28%) | 12% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Baseline | ~55^1^/552 (10%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Advance care plan or surrogate decision maker documented in the EHR (or documentation that the patient did not wish to have this documented) | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (11%) | 1% | Process

Notes.

a Initial implementation phase to a later time point

b Study compared results at 3 pilot sites to 18 sites after they implemented strategies at a later date. Because all 21 sites implemented the same strategies we reported this as a single group pre-post study

c Calculated by the research team

d Reported mostly single group outcomes, but also compared sites that implemented 2 specific strategies (Virtual Clinic strategy and PDSA strategy) to sites that did not implement the strategies, therefore used as single group (baseline-later time point) design for sites that did not already have AFHS and NRCS for sites with existing AFHS

e Study compared a site that incorporated a templated note as part of their electric health record to a site that implemented AFHS but did not use a templated note. Because the overall strategies and 4Ms assessments were different between sites, we reported this as a single group study

f Study reported 2 different strategies implemented at 2 different sites, which we reported as a single group pre-post study, though 1 site had post-only data.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; ACP=advanced care planning; AWV=annual wellness visit; EHR=electronic health record; GeriPACT=geriatric patient aligned care teams; HBPC=home-based primary care; NR=not reported; RD=risk difference; RN=registered nurse; QI=quality improvement.

## K2. Medication

Author, Year, PMID, Study Design | Details | Population | Follow-Up | Groups/Comparators | N/N (%) | Effect Size (95% CI), Reported P Value/ Absolute Difference
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | High-risk medication elimination | All | June 2020-Jan 2022 | Baseline 3 Pilot 4Ms sites | 177/337 (53%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | High-risk medication elimination | All | June 2020-Jan 2022 | 3 Pilot 4Ms sites | 226/397 (57%) | RD 0.04 (−0.03, 0.12)^c^ | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | High-risk medication elimination | All | June 2020-Jan 2022 | 18 comparison sites | 4112/6527 (63%) | - | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Opioid misuse mitigation | All | June 2020-Jan 2022 | Baseline 3 Pilot 4Ms sites | 31/40 (78%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Opioid misuse mitigation | All | June 2020-Jan 2022 | 3 Pilot 4Ms sites | 22/23 (96%) | RD 0.18 (0.03, 0.34)^c^ | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Opioid misuse mitigation | All | June 2020-Jan 2022 | 18 comparison sites | 5613/6527 (86%) | - | Process
Guth, 2020, 32976620, Single group (Pre-post) | “Usually” or “Always” discussing 4Ms during high-risk rounds (provider reported) - Medication | Providers | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Pre-intervention | 7/11 (63.6%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | “Usually” or “Always” discussing 4Ms during high-risk rounds (provider reported) - Medication | Providers | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Post intervention | 10/11 (90.9%) | RD 0.27 (−0.06, 0.60)^c^ | Process
Guth, 2020, 32976620, Single group (Pre-post) | Medication: Patient was seen by the Center for Successful Aging’s onsite pharmacist and completed a medication review. | Snapshot of patients before training in 4Ms and after | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Pre-implementation | 57/67 (85%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | Medication: Patient was seen by the Center for Successful Aging’s onsite pharmacist and completed a medication review. | Snapshot of patients before training in 4Ms and after | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Post-implementation | 47/55 (85%) | RD 0.00 (−0.12, 0.13)^c^ | Process
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “Medication” | Eligible patients completing 4Ms | First 8 months vs. February 2022 | First 8 months | 3.1% | | Process
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “Medication” | Eligible patients completing 4Ms | First 8 months vs. February 2022 | February 2022 | 21.9% | 18.8% | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | Health Factors Addressed (Medication)- Medication review and reconciliation; Or; High-risk medications are reviewed, documented, deprescribed, and avoided. If Medication is necessary, the Medication does not interfere with What Matters to the older Veteran, their Mobility, or Mentation. | All | During 30-day period | GeriPACT Non-Templated Notes | 64/127 (50%) | - | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | | All | During 30-day period | GeriPACT and HBPC Templated Notes | 12/49 (24%) | - | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Medication—Review and reconciliation | All | Oct-Dec 2021 | University Clinic- Needs Assessment | 146/146 (100%) | | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Medication—Review and reconciliation | All | Sep-Dec 2022 | University Clinic- After QI Implementation | 15/15 (100%) | RD 0.00 (0.00, 0.00)^c^ | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Medication—Review and reconciliation | All | Dec 2022-Mar 2023 | Health Center- After QI Implementation | 6/6 (100%) | - | Process
Tewary, 2023, 36062563, Single group (Pre-post) | High risk medications in elderly | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Baseline (2019) | No data available | - | Process
Tewary, 2023, 36062563, Single group (Pre-post) | High risk medications in elderly | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Year 1 (2020) | 3.71% (Improving)^g^ | - | Process
Vonnes, 2023, 37783590, Single group (Post only) | Medication history screening that prompted pharmacy consult | All | screening period | geriatric oncology patients | 836/1044 (80.1%) | - | Process
Vonnes, 2023, 37783590, Single group (Post only) | Pharmacy collaborated for high-risk medications including anticoagulants and oral hypoglycemic agents | All | screening period | geriatric oncology patients | 146/1044 (14.0%) | - | Process
Vonnes, 2023, 37783590, Single group (Post only) | Pharmacy collaborated for deprescribing opportunities in patients taking proton pump inhibitors, aspirin for primary prevention or potentially inappropriate medications | All | screening period | geriatric oncology patients | 195/1044 (18.7%) | - | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Baseline | ~80/725 (11 %) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (7%) | −4% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Baseline | ~346/1441 (24%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (23%) | −1% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Baseline | ~681/1703 (20%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (22%) | 2% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Baseline | ~554/1386 (40%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (39%) | −1% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Baseline | ~77/552 (14%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Currently prescribed an opioid and a sedative-hypnotic (benzo or z-drug) with 2 or more prescriptions in the last 12 months | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (10%) | −4% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Baseline | ~22/725 (3%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (6%) | 3% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Baseline | ~288/1441 (20%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (10%) | −10% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Baseline | ~238/1703 (15%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (17%) | 2% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Baseline | ~194/1386 (14%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (14%) | 0% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Baseline | ~77/552 (14%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Chronic Opioid Use | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (16%) | 2% | Process

Notes.

a Initial implementation phase to a later time point

b Study compared results at 3 pilot sites to 18 sites after they implemented strategies at a later date. Because all 21 sites implemented the same strategies we reported this as a single group pre-post study

c Calculated by the research team

d Reported mostly single group outcomes, but also compared sites that implemented 2 specific strategies (Virtual Clinic strategy and PDSA strategy) to sites that did not implement the strategies, therefore used as single group (baseline-later time point) design for sites that did not already have AFHS and NRCS for sites with existing AFHS

e Study compared a site that incorporated a templated note as part of their electric health record to a site that implemented AFHS but did not use a templated note. Because the overall strategies and 4Ms assessments were different between sites, we reported this as a single group study

f Study reported 2 different strategies implemented at 2 different sites, which we reported as a single group pre-post study, though 1 site had post-only data

g 8.52% was reported in the study but it was not clear what this was reporting on.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; GeriPACT=geriatric patient aligned care teams; HBPC=home-based primary care; NR=not reported; RD=risk difference; QI=quality improvement.

## K3. Mentation

Author, Year, PMID, Study Design | Details | Population | Follow-Up | Groups/ Comparators | N/N (%) | Effect Size (95% CI), Reported P Value/ Absolute Difference
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Dementia monitoring | All | June 2020-Jan 2022 | Baseline 3 Pilot 4Ms sites | 5/12 (42%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Dementia monitoring | All | June 2020-Jan 2022 | 3 Pilot 4Ms sites | 9/15 (60%) | RD 0.18 (−0.19, 0.56)^c^ | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Dementia monitoring | All | June 2020-Jan 2022 | 18 comparison sites | 4634/6527 (71%) | - | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Dementia screening | All | Jan 2021-Jan 2022 | Baseline 3 Pilot 4Ms sites | 1/328 (0%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Dementia screening | All | Jan 2021-Jan 2022 | 3 Pilot 4Ms sites | 95/397 (24%) | RD 0.24 (0.19, 0.28)^c^ | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Dementia screening | All | Jan 2021-Jan 2022 | 18 comparison sites | 783/6527 (12%) | - | Process
Guth, 2020, 32976620, Single group (Pre-post) | “Usually” or “Always” discussing 4Ms during high-risk rounds (provider reported) - Mentation | Providers | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Pre-intervention | 6/11 (54.5%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | “Usually” or “Always” discussing 4Ms during high-risk rounds (provider reported) - Mentation | Providers | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Post intervention | 10/11 (90.9%) | RD 0.36 (0.02, 0.70)^c^ | Process
Guth, 2020, 32976620, Single group (Pre-post) | Mentation: Patient completed any of the following cognitive screenings with a provider: Mini Mental State Examination, Montreal Cognitive Assessment, Patient Health Questionnaire, or Geriatric Depression Scale. | Snapshot of patients before training in 4Ms and after | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Pre-implementation | 55/67 (82%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | | Snapshot of patients before training in 4Ms and after | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Post-implementation | 47/55 (85%) | RD 0.03 (−0.10, 0.16)^c^ | Process
Lundy, 2021, 33275785, Single group (Post only) | Rapid Cognitive Screen (RCS) | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | Normal | ~818/1326 (61.7%) | - | Outcome
Lundy, 2021, 33275785, Single group (Post only) | Rapid Cognitive Screen (RCS) | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | Mild cognitive impairment | ~232/1326 (17.5%) | | Outcome
Lundy, 2021, 33275785, Single group (Post only) | Rapid Cognitive Screen (RCS) | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | Dementia | ~276/1326 (20.8%) | | Outcome
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “Mentation” | Eligible patients completing 4Ms | First 8 months vs. February 2022 | First 8 months | 0.8% | | Process
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “Mentation” | Eligible patients completing 4Ms | First 8 months vs. February 2022 | February 2022 | 9% | ~8% | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | Health Factors Addressed (Mentation)- Mini-Cog and PHQ2; Or; Awareness of cognitive impairment warning signs to prompt the evaluation of cognition. Depression and delirium are prevented, identified, treated, and managed. Changes in mood or mental health are identified and managed | All | During 30-day period | GeriPACT Non-Templated Notes | 36/127 (24%) | - | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | | All | During 30-day period | GeriPACT and HBPC Templated Notes | 14/49 (29%) | | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Mentation—Depression or cognition addressed (PHQ2, qualitative comments mostly) few MOCA, Mini-Cog, MMSE | All | Oct-Dec 2021 | University Clinic- Needs Assessment | 41/146 (28%) | | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Mentation—Depression or cognition addressed (PHQ2, qualitative comments mostly) few MOCA, Mini-Cog, MMSE | All | Sep-Dec 2022 | University Clinic- After QI Implementation | 13/15 (86.6%) | RD 0.59 (0.40, 0.77)^1^ | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Mentation—Depression or cognition addressed (PHQ2, qualitative comments mostly) few MOCA, Mini-Cog, MMSE | All | Dec 2022-Mar 2023 | Health Center- After QI Implementation | 6/6 (100%) | - | Process
Tewary, 2023, 36062563, Single group (Pre-post) | Diabetes management poor control | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Baseline (2019) | 8.82% | | Process
Tewary, 2023, 36062563, Single group (Pre-post) | Diabetes management poor control | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Year 1 (2020) | 22.73% (Worsening) | 13.91% | Process
Tewary, 2023, 36062563, Single group (Pre-post) | HTN management adequately controlled | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Baseline (2019) | 78.43% | | Process
Tewary, 2023, 36062563, Single group (Pre-post) | HTN management adequately controlled | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Year 1 (2020) | 63.24% (Worsening) | −15.19% | Process
Tewary, 2023, 36062563, Single group (Pre-post) | Dementia caregiver education | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Baseline (2019) | No data available | | Process
Tewary, 2023, 36062563, Single group (Pre-post) | Dementia caregiver education | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Year 1 (2020) | 1.61% (Improving) | - | Process
Vonnes, 2023, 37783590, Single group (Post only) | Abnormal cognition screening results referred to pharmacy for medication adherence review | All | screening period | geriatric oncology patients | 184/246 (74.8%) | - | Process
Vonnes, 2023, 37783590, Single group (Post only) | Had abnormal Mini-Cog | All | screening period | geriatric oncology patients | 246/1044 (23.6%) | - | Outcome
Vonnes, 2023, 37783590, Single group (Post only) | Received social work consults | All | screening period | geriatric oncology patients | 381/1044 (36.5%) | - | Process
Vonnes, 2023, 37783590, Single group (Post only) | Patients missing results in SAOP-3. | All | screening period | geriatric oncology patients | 280/1044 (26.8%) | - | Process
Vonnes, 2023, 37783590, Single group (Post only) | Screened positive for depression via PHQ-2 | All | screening period | geriatric oncology patients | 91/1044 (8.7%)^c^ | | Outcome
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Baseline | ~22^1^/725 (3%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (64%) | 61% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Baseline | ~620^1^/1441 (43%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (52%) | 9% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Baseline | ~1328^1^/1703 (27%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (40%) | 13% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Baseline | ~1081^1^/1386 (78%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (80%) | 2% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Baseline | ~425^1^/552 (77%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for cognitive impairment in the last 12 months | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (81%) | 4% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Baseline | ~22^1^/725 (3%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (80%) | 77% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Baseline | ~735^1^/1441 (51%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (77%) | 26% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Baseline | ~1533^1^/1703 (34%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (48%) | 14% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Baseline | ~1247^1^/1386 (90%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (88%) | −2% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Baseline | ~475^1^/552 (86%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Age-Friendly Quality Measure Performance (Dementia Cognitive Assessment) | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (89%) | 3% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Patients with a dementia diagnosis whose caregiver was provided with education on dementia disease management and health behavior changes and referred to additional resources for support within the last 12 months | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Baseline | 0/725 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (21%) | 21% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Baseline | 0/1441 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (8%) | 8% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Baseline | 0/1703 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (2%) | 2% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Baseline | 0/1386 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (0%) | 0% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Baseline | 0/552 (0%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (0%) | 0% | Process

Notes.

a Initial implementation phase to a later time point

b Study compared results at 3 pilot sites to 18 sites after they implemented strategies at a later date. Because all 21 sites implemented the same strategies, we reported this as a single group pre-post study

c Calculated by the research team

d Reported mostly single group outcomes, but also compared sites that implemented 2 specific strategies (Virtual Clinic strategy and PDSA strategy) to sites that did not implement the strategies, therefore used as single group (baseline-later time point) design for sites that did not already have AFHS and NRCS for sites with existing AFHS

e Study compared a site that incorporated a templated note as part of their electric health record to a site that implemented AFHS but did not use a templated note. Because the overall strategies and 4Ms assessments were different between sites, we reported this as a single group study

f Study reported 2 different strategies implemented at 2 different sites, which we reported as a single group pre-post study, though 1 site had post-only data

g 8.52% was reported in the study but it was not clear what this was reporting on.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; GeriPACT=geriatric patient aligned care teams; HBPC= home-based primary care; HTN=hypertension; MOCA=Montreal Cognitive Assessment; MMSE=mini mental status exam; NR=not reported; PHQ2=Patient Health Questionnaire-2; RCS=rapid cognitive screen; RGA=rapid geriatric assessment; RD=risk difference; SOAP=Senior Adult Oncology Program; QI=quality improvement.

## K4. Mobility

Author, Year, PMID, Study Design | Details | Population | Follow-Up | Groups/Comparators | N/N (%) | Effect Size (95% CI), Reported P Value/ Absolute Difference
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Fall risk management | All | June 2020-Jan 2022 | Baseline 3 Pilot 4Ms sites | 0/8 (0%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Fall risk management | All | June 2020-Jan 2022 | | | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Fall risk management | All | June 2020-Jan 2022 | 3 Pilot 4Ms sites | 45/105 (43%) | RD 0.43 (0.33, 0.52)^c^ | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Fall risk management | All | June 2020-Jan 2022 | | | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Fall risk management | All | June 2020-Jan 2022 | 18 comparison sites | 653/6527 (10%) | - | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Mobility goal completion | All | Jan 2021-Jan 2022 | Baseline 3 Pilot 4Ms sites | 1/328 (0%) | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Mobility goal completion | All | Jan 2021-Jan 2022 | | | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Mobility goal completion | All | Jan 2021-Jan 2022 | 3 Pilot 4Ms sites | 75/397 (19%) | RD 0.19 (0.15, 0.22)^c^ | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Mobility goal completion | All | Jan 2021-Jan 2022 | | | | Process
Berish, 2023, 36129432, Single group; (Baseline-Later Time point)^a,b^ | Mobility goal completion | All | Jan 2021-Jan 2022 | 18 comparison sites | 587/6527 (9%) | - | Process
Guth, 2020, 32976620, Single group (Pre-post) | “Usually” or “Always” discussing 4Ms during high-risk rounds (provider reported) - Mobility | Providers | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Pre-intervention | 3/11 (27.3%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | “Usually” or “Always” discussing 4Ms during high-risk rounds (provider reported) - Mobility | Providers | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | | | | Process
Guth, 2020, 32976620, Single group (Pre-post) | “Usually” or “Always” discussing 4Ms during high-risk rounds (provider reported) - Mobility | Providers | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Post intervention | 7/11 (63.6%) | RD 0.36 (−0.02, 0.75)^c^ | Process
Guth, 2020, 32976620, Single group (Pre-post) | Mobility: Patient was seen by the Center for Successful Aging’s onsite physical therapist OR was referred to outpatient physical therapy by a provider. | Snapshot of patients before training in 4Ms and after | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Pre-intervention | 37/67 (55%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | Mobility: Patient was seen by the Center for Successful Aging’s onsite physical therapist OR was referred to outpatient physical therapy by a provider. | Snapshot of patients before training in 4Ms and after | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | | | | Process
Guth, 2020, 32976620, Single group (Pre-post) | Mobility: Patient was seen by the Center for Successful Aging’s onsite physical therapist OR was referred to outpatient physical therapy by a provider. | Snapshot of patients before training in 4Ms and after | Pre- vs. post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Post intervention | 38/55 (69%) | RD 0.14 (−0.03, 0.31)^c^ | Process
Lundy, 2021, 33275785, Single group (Post-only) | SARC-F Results | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | Sarcopenia | ~558^1^/1326 (42.1%) | - | Outcome
Lundy, 2021, 33275785, Single group (Post-only) | SARC-F Results | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | | | | Outcome
Lundy, 2021, 33275785, Single group (Post-only) | SARC-F Results | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | No sarcopenia | ~768^1^/1326 (57.9%) | - | Outcome
Lundy, 2021, 33275785, Single group (Post only) | Falls in the last year (1–3 falls in the last year) | Patients receiving a rapid geriatric assessment (RGA) | At assessment | 1–3 falls in the last year | ~424^1^/1326 (32%) | - | Outcome
Lundy, 2021, 33275785, Single group (Post only) | Falls in the last year (1–3 falls in the last year) | Patients receiving a rapid geriatric assessment (RGA) | At assessment | | | | Outcome
Lundy, 2021, 33275785, Single group (Post only) | Falls in the last year (1–3 falls in the last year) | Patients receiving a rapid geriatric assessment (RGA) | At assessment | 4 or more fall in the last year | ~114^1^/1326 (8.6%) | - | Outcome
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “Mobility” following the implementation of a best practice alert in the EHR | Eligible patients completing 4Ms | First 8 months vs. February 2022 | First 8 months | 2.0% | | Process
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “Mobility” following the implementation of a best practice alert in the EHR | Eligible patients completing 4Ms | First 8 months vs. February 2022 | | | | Process
Pohnert, 2023, 36134714, NRCS^d^ | Completion of “Mobility” following the implementation of a best practice alert in the EHR | Eligible patients completing 4Ms | First 8 months vs. February 2022 | February 2022 | 12.5% | 10.5% | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | Health Factors Addressed (Mobility)- ADL mobility questions; Or; Mobility limitations are identified, and it is ensured that each older Veteran moves safely every day to maintain function and do What Matters | All | During 30-day period | GeriPACT Non-Templated Notes | 68/127 (54%) | - | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | | All | During 30-day period | | | | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | | All | During 30-day period | GeriPACT and HBPC Templated Notes | 12/49 (24%) | - | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Mobility addressed (falls questions, TUG test, exercise, PT referral) | All | Oct-Dec 2021 | University Clinic- Needs Assessment | 57/146 (39%) | | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Mobility addressed (falls questions, TUG test, exercise, PT referral) | All | | | | | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Mobility addressed (falls questions, TUG test, exercise, PT referral) | All | Sep-Dec 2022 | University Clinic- After QI Implementation | 15/15 (100%) | RD 0.61 (0.53, 0.69)^c^ | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Mobility addressed (falls questions, TUG test, exercise, PT referral) | All | | | | | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Mobility addressed (falls questions, TUG test, exercise, PT referral) | All | Dec 2022-Mar 2023 | Health Center- After QI Implementation | 6/6 (100%) | - | Process
Tewary, 2023, 36062563, Single group (Pre-post) | Falls Risk Assessment | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Baseline (2019) | No data available | - | Process
Tewary, 2023, 36062563, Single group (Pre-post) | Falls Risk Assessment | Clinics completing all components of Phases 1 and 2 | Baseline vs. follow up | Year 1 (2020) | 46.72% (Improving) | | Process
Vonnes, 2023, 37783590, Single group (Post only) | Fall risk screening at registration | All | screening period | geriatric oncology patients | ~1699^1^/1770 (96%) | - | Process
Vonnes, 2023, 37783590, Single group (Post only) | Baseline TUG >12.0 s | All | screening period | screening period | 376/1770 (21.2%) | - | Outcome
Vonnes, 2023, 37783590, Single group (Post only) | Missing TUG assessment at first visit | All | screening period | screening period | 37 | | Process
Vonnes, 2023, 37783590, Single group (Post only) | Baseline falls within one month of TUG | All | screening period | geriatric oncology patients | ~212^1^/1770 (12%) | | Outcome
Vonnes, 2023, 37783590, Single group (Post only) | Peripheral neuropathy | All | screening period | geriatric oncology patients | ~248^1^/1770 (14%) | | Outcome
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Baseline | 551/725 (76%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | | | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Geriatrics | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (98%) | 22% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | | | | | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Baseline | ~1369^1^/1441 (95%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | | | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Internal medicine | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (89%) | −6% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | | | | | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Baseline | ~1669^1^/1703 (83%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | | | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Family medicine A | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (85%) | 2% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | | | | | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Baseline | ~1358^1^/1386 (98%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | | | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Family medicine B | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (96%) | −2% | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | | | | | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Baseline | ~508^1^/552 (92%) | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | | | | Process
Wismann, 2024, 38488173, Single group (Pre-post) | Screened for future fall risk within the last 12 months | Adults aged ≥ 65 years in Family medicine C | Baseline for the first two quarters of 2023 | Q2-3 2023 | NR/NR (93%) | 1% | Process

Notes.

a Initial implementation phase to a later time point

b Study compared results at 3 pilot sites to 18 sites after they implemented strategies at a later date. Because all 21 sites implemented the same strategies we reported this as a single group pre-post study

c Calculated by the research team

d Reported mostly single group outcomes, but also compared sites that implemented 2 specific strategies (Virtual Clinic strategy and PDSA strategy) to sites that did not implement the strategies, therefore used as single group (baseline-later time point) design for sites that did not already have AFHs and NRCS for sites with existing AFHS

e Study compared a site that incorporated a templated note as part of their electric health record to a site that implemented AFHS but did not use a templated note. Because the overall strategies and 4Ms assessments were different between sites, we reported this as a single group study

f Study reported 2 different strategies implemented at 2 different sites, which we reported as a single group pre-post study, though 1 site had post-only data.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; ADL=activities of daily living; EHR=electronic health record; GeriPACT=geriatric patient aligned care teams; HBPC=home-based primary care; NR=not reported; PT=physical therapy; RD=risk difference; RGA=rapid geriatric assessment; RN=registered nurse; SARC-F=Strength, Assistance with walking, Rise from a chair, Climb stairs and Falls; TUG=timed up and go test.

## K5. Composite and Other^a,b^

Author, Year, PMID, Study Design | Details | Population | Follow-Up | Groups/Comparators | N/N (%) | Effect Size (95% CI), Reported P Value/ Absolute Difference
Garbarino, 2023, 38038359, Single group (Pre-post) | Number of RN-led AWVs | All | Pre- vs. post-intervention (May-Oct 2021) | Pre-intervention | 19 | - | Process
Garbarino, 2023, 38038359, Single group (Pre-post) | Number of RN-led AWVs | All | Pre- vs. post-intervention (May-Oct 2021) | Post intervention | 58 | - | Process
Garbarino, 2023, 38038359, Single group (Pre-post) | Number of provider-led AWVs | All | Pre- vs post-intervention (May-Oct 2021) | Pre-intervention | 72 | - | Process
Garbarino, 2023, 38038359, Single group (Pre-post) | Number of provider-led AWVs | All | Pre- vs post-intervention (May-Oct 2021) | Post intervention | 41 | | Process
Garbarino, 2023, 38038359, Single group (Pre-post) | Completion of RN-led AWVs | All | 2020 vs Follow up (2021) | Pre-intervention | 24 | - | Process
Garbarino, 2023, 38038359, Single group (Pre-post) | Completion of RN-led AWVs | All | 2020 vs Follow up (2021) | Post intervention | 150 | - | Process
Guth, 2020, 32976620, Single group (Pre-post) | Team escalates interventions/intensity of care “Usually” or “Always” (provider reported) | Providers | Pre- vs post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Pre-intervention | 8/11 (72.7%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | Team escalates interventions/intensity of care “Usually” or “Always” (provider reported) | Providers | | Post intervention | 5/10 (50%) | RD −0.23 (−0.63, 0.18) | Process
Guth, 2020, 32976620, Single group (Pre-post) | Team discusses outcome/impact of prior intervention “Usually” or “Always” (provider reported) | Providers | Pre- vs post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Pre-intervention | 5/11 (45.5%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | Team discusses outcome/impact of prior intervention “Usually” or “Always” (provider reported) | Providers | Pre- vs post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Post intervention | 6/11 (54.5%) | RD 0.09 (−0.33, 0.51)^c^ | Process
Guth, 2020, 32976620, Single group (Pre-post) | High risk rounds discussion informs and guides care plan “Usually” or “Always” (provider reported) | Providers | Pre- vs post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Pre-intervention | 4/11 (36.4%) | | Process
Guth, 2020, 32976620, Single group (Pre-post) | High risk rounds discussion informs and guides care plan “Usually” or “Always” (provider reported) | Providers | Pre- vs post-implementation (Oct- Dec 2018 vs Jan-Mar 2019) | Post intervention | 4/9 (44.4%) | RD 0.08 (−0.35, 0.51)^c^ | Process
Lundy, 2021, 33275785, Single group (Post only) | Screened with the RGA | Adults 65 years and older | At assessment | Older adults in service area | 1,326/NR (38%) | - | Process
Lundy, 2021, 33275785, Single group (Post only) | FRAIL results | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | Not frail | ~430/1326 (32.4%) | - | Outcome
Lundy, 2021, 33275785, Single group (Post only) | FRAIL results | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | Pre-frail | ~414/1326 (31.2%) | - | Outcome
Lundy, 2021, 33275785, Single group (Post only) | FRAIL results | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | Frail | ~484/1326 (36.5%) | - | Outcome
Lundy, 2021, 33275785, Single group (Post only) | SNAQ Results | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | Not at risk for weight loss | ~980/1326 (73.9%) | - | Outcome
Lundy, 2021, 33275785, Single group (Post only) | SNAQ Results | Patients receiving a rapid geriatric assessment (RGA) | At assessment (July 1, 2015-June 30, 2019) | At risk for weight loss | ~346/1326 (26.1%) | | Outcome
Pohnert, 2023, 36134714, NRCS^d^ | Improvement in “M-Score performance” (mean number of Ms delivered per visit) | Eligible patients completing 4Ms | Baseline vs follow up (2022) | Baseline | Mean 0.11 | | Process
Pohnert, 2023, 36134714, NRCS^d^ | Improvement in “M-Score performance” (mean number of Ms delivered per visit) | Eligible patients completing 4Ms | Baseline vs follow up (2022) | Follow up | Mean 0.73 | Mean difference 0.62 | Process
Pohnert, 2023, 36134714, NRCS^d^ | Number of regions achieving IHI Regional Committed to Care Excellence recognition | All | follow up | MinuteClinics implementing 4Ms | 74/74 (100%) | - | Structural
Pohnert, 2023, 36134714, NRCS^d^ | Completion of all 4Ms | Eligible patients completing 4Ms | First 8 months vs February 2022 | First 8 months | <1% | | Process
Pohnert, 2023, 36134714, NRCS^d^ | Completion of all 4Ms | Eligible patients completing 4Ms | First 8 months vs February 2022 | February 2022 | 5.84% | ~4.84% | Process
Pohnert, 2023, 36134714, NRCS^d^ | Ms delivered | Eligible patients completing 4Ms | Follow up (Year 2) | Virtual Clinic strategy patients | NR/NR (NR) | | Process
Pohnert, 2023, 36134714, NRCS^d^ | Ms delivered | Eligible patients completing 4Ms | Follow up (Year 2) | Control group | NR/NR (NR) | IRR 2.47 (1.42, 4.28) p = NR | Process
Pohnert, 2023, 36134714, NRCS^d^ | Ms delivered | Eligible patients completing 4Ms | Follow up (Year 2) | PDSA intervention strategy patients | NR/NR (NR) | | Process
Pohnert, 2023, 36134714, NRCS^d^ | Ms delivered | Eligible patients completing 4Ms | Follow up (Year 2) | Control group | NR/NR (NR) | IRR 3.08 (1.19, 7.94) p = NR | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | Health Factors Addressed (indeterminate) | All | During 30-day period | GeriPACT Non-Templated Notes | NR/127 (NR) | | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | Health Factors Addressed (indeterminate) | All | During 30-day period | GeriPACT and HBPC Templated Notes | 5/49 (10%) | - | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | 4 Health Factors (4Ms) Addressed | All | During 30-day period | GeriPACT Non-Templated Notes | 1/127 (1%) | | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | 4 Health Factors (4Ms) Addressed | All | During 30-day period | GeriPACT and HBPC Templated Notes | 20/49 (41%) | - | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | 3 Health Factors (4Ms) Addressed | All | During 30-day period | GeriPACT Non-Templated Notes | 16/127 (13%) | | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | 3 Health Factors (4Ms) Addressed | All | During 30-day period | GeriPACT and HBPC Templated Notes | 12/49 (24%) | - | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | 2 Health Factors (4Ms) Addressed | All | During 30-day period | GeriPACT Non-Templated Notes | 38/127 (30%) | - | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | 2 Health Factors (4Ms) Addressed | All | During 30-day period | GeriPACT and HBPC Templated Notes | 5/49 (10%) | | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | 1 Health Factors (4Ms) Addressed | All | During 30-day period | GeriPACT Non-Templated Notes | 72/127 (56%) | | Process
Powers, 2022, 36286213, Single group^e^ (Post only) | 1 Health Factors (4Ms) Addressed | All | During 30-day period | GeriPACT and HBPC Templated Notes | 7/49 (13%) | - | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | Medicare Preventive template completion (falls, function, PHQ2, mentation, ACP discussion) | All | Oct-Dec 2021 | University Clinic- Needs Assessment | 20/146 (13.7%) | - | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | All 4Ms were completed, including objective cognitive screening | All | Oct-Dec 2021 | University Clinic- Needs Assessment | 3/146 (2%) | | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | All 4Ms were completed, including objective cognitive screening | All | Sep-Dec 2022 | University Clinic- After QI Implementation | 13/15 (86.6%) | RD 0.85 (0.67, 1.02)^c^ | Process
Tewary, 2023, 37489318, Single group (Pre-post)^f^ | All 4Ms were completed, including objective cognitive screening | All | Dec 2022-Mar 2023 | Health Center- After QI Implementation | 6/6 (100%) | - | Process

Notes.

a Results about N of providers included in the studies were considered to be features of the study

b Result about provider knowledge about responsible team member, knowledge of the intervention, or agreement with risk level were not extracted from Guth et al as these were not considered to be related to AFHS implementation

c Calculated by the research team

d Reported mostly single group outcomes, but also compared sites that implemented 2 specific strategies (Virtual Clinic strategy and PDSA strategy) to sites that did not implement the strategies, therefore used as single group (baseline-later time point) design for sites that did not already have AFHS and NRCS for sites with existing AFHS

e Study compared a site that incorporated a templated note as part of their electric health record to a site that implemented AFHS but did not use a templated note. Because the overall strategies and 4Ms assessments were different between sites, we reported this as a single group study

f Study reported 2 different strategies implemented at 2 different sites, which we reported as a single group pre-post study, though 1 site had post-only data.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; ACP=advance care planning; AWV=annual wellness visit; FRAIL=Fatigue, Resistance, Ambulation, Illness, Loss of weight; GeriPACT=geriatric patient aligned care teams; HBPC=home-based primary care; HTN=hypertension; IHI= Institute for Healthcare Improvement; NR=not reported; PDSA=plan do study act; RGA=rapid geriatric assessment; RN=registered nurse; RD=risk difference; SNAQ=Simplified Nutrition Appetite Questionnaire; SOAP=Senior Adult Oncology Program; QI=quality improvement.